# STAKEHOLDER AND TECHNICAL EXPERT PANEL

In designing the study questions and methodology at the outset of this report, the ESP consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

The list of stakeholders and members of the Technical Expert Panel (TEP) who provided input to this report follows.

## Stakeholders

- Katherine Faricy-Anderson, MD, MPH
  Chair, Association of VA Hematology/Oncology Palliative Care Research Committee
  Providence VA Medical Center
- Scott Shreve, DO
  Director, Hospice and Palliative Care Program
  Office of Patient Care Services, Geriatrics and Extended Care

## Technical Expert Panel

- Katja Elbert-Avila, MD, MHS
  Palliative Medicine Attending, Durham Veterans Affairs Health Care System
  Assistant Professor, Division of Geriatrics, Duke University Medical Center
- Michael Kelley, MD
  Chief, Hematology/Oncology, Durham Veterans Affairs Health Care System
  Professor, Division of Medical Oncology, Duke University Medical Center
- Cari Levy, MD
  Associate Professor of Medicine, Division of Health Care Policy & Research
  University of Colorado
- Karl Lorenz, MD
  Section Chief, VA Palo Alto, Stanford Palliative Care Programs
  Director, VA Palliative Care Quality Improvement Resource Center