# APPENDIX H STUDY CHARACTERISTICS FOR KEY QUESTIONS 1 AND 2

For full study citations, please refer to the report's main reference list.

Study Location Total N | Intervention Setting Comparator Time Since Diagnosis | Mean Age in Years % Female Veteran? | % Cancer Type Severity or Prognosis | Outcomes Reported | ROB by Outcome Category
Bakitas, 2009^12^ United States 322 | Outpatient Usual care 8-12 weeks | Int: 64.7 Com: 65.4 Int: 40.4% Com: 43.5% Yes | Lung: 36-37% GI: 41-42% Breast: 10-11% GU: 11-12% Stage III or IV | [underlined: Patient] Mental status QOL Disease symptoms Survival Health services use | Objective: Low Patient-reported: Low
Bakitas, 2015^41^ United States 207 | Home Delayed palliative care Within 30-60 days of diagnosis or recurrence | Int: 64.0 Com: 64.6 Int: 46.2% Com: 48.5% Yes | Lung: 41-44% GI: 23-25% Breast: 10-12% Other: 21-23% Advanced stage | [underlined: Patient] Mental status QOL Disease symptoms Survival Health services use | Objective: Unclear Patient-reported: Unclear
Clark, 2013^43^ United States 138 | Outpatient Usual care Within 12 months | Int: 58.7 Com: 59.9 Int: 37% Com: 32% No | Lung: 11-15%, GI: 36-39% Other: 46-53% Advanced stage ECOG range 0-2 | [underlined: Patient] Mental status QOL [underlined: Caregiver] Experience (QOL) | Objective: NR/NA Patient-reported: High
Maltoni, 2016^39^ Europe 207 | Outpatient Standard care plus on demand PC Within 8 weeks | Int: 67 (median) Com: 66 (median) Int: 38.5% Com: 47.2% No | Pancreatic: 100% inoperable or metastatic >2 months | [underlined: Patient] Mental status QOL Disease symptoms Care experience Health service use | Objective: Unclear Patient-reported: High
McCorkle, 2015^40^ United States 146 | Outpatient Enhanced usual care Within 100 days | Int: 51.5% <age 65 Com: 71.3% <age 65 Int: 71.2% Com: 43.7% No | Intervention: Lung: 56.1% Gyn: 43.9% Comparator: GI: 66.2% Head/neck: 33.8% Late-stage | [underlined: Patient] Physical status Mental status QOL Disease symptoms | Objective: Unclear Patient-reported: High
Rummans, 2006^44^ United States 115 | Outpatient Usual care Within 12 months | Int: 59.7 Com: 59.4 Int: 40.8% Com: 31.5% No | Lung: 11-18% GI: 36-39%, Other: 45-50% Prognosis > 6 month | [underlined: Patient] Mental status QOL [underlined: Caregiver:] Experience (QOL) | Objective: NR/NA Patient-reported: Unclear
Temel, 2010^14^ United States 151 | Outpatient Usual care Within 8 weeks | Int: 65.0 Com: 64.9 Int: 55% Com: 49% No | Lung: 100% Metastatic ECOG range 0-2 | [underlined: Patient] Mental status QOL Survival Site of death Health service use | Objective: Low Patient-reported: Unclear
Temel 2017^45^ United States 350 | Outpatient Usual care Within 8 weeks | Int: 65.64 Com: 64.03 Int: 48% Com: 44% No | [underlined: Int] Lung: 54.3% GI: 20.6% Pancreatic: 25.1% [underlined: Com] Lung: 54.9% GI: 20.6% Pancreatic: 24.6% NR other than eligibility of “incurable” | [underlined: Patient] Mental status QOL | Objective: NR/NA Patient-reported: Low
Zimmermann, 2014^42^ Canada 461 | Outpatient Usual care NR | Int: 61.2 Com: 60.2 Int: 59.6% Com: 53.6% No | Lung: 20-24% Gl: 28-33% Gyn/GU: 25-39% Stage III or IV ECOG range 0-2 | [underlined: Patient] QOL Disease symptoms Health service use [underlined: Caregiver] Family satisfaction with patient care | Objective: Low Patient-reported: Unclear

Abbreviations: Com=comparator; ECOG=Eastern Cooperative Oncology Group; GI=gastrointestinal; GU=genitourinary; Gyn=gynecologic; Int=intervention; NA=not applicable; NR=not reported; QOL=quality of life