# APPENDIX G PEER REVIEW COMMENTS

Question Text | Comment | Response
Are the objectives, scope, and methods for this review clearly described? | Yes | Acknowledged, thank you.
Are the objectives, scope, and methods for this review clearly described?
Are the objectives, scope, and methods for this review clearly described? | Yes | Acknowledged, thank you.
Are the objectives, scope, and methods for this review clearly described?
Are the objectives, scope, and methods for this review clearly described? | Yes | Acknowledged, thank you.
Are the objectives, scope, and methods for this review clearly described?
Are the objectives, scope, and methods for this review clearly described? | Yes | Acknowledged, thank you.
Are the objectives, scope, and methods for this review clearly described?
Are the objectives, scope, and methods for this review clearly described? | Yes | Acknowledged, thank you.
Q2
Is there any indication of bias in our synthesis of the evidence? | No | Acknowledged, thank you.
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | No | Acknowledged, thank you.
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | No | Acknowledged, thank you.
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | No | Acknowledged, thank you.
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | No | Acknowledged, thank you.
Q3
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | Acknowledged, thank you.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | Acknowledged, thank you.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | Acknowledged, thank you.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | Acknowledged, thank you.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | Acknowledged, thank you.
Q4
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | VA ESP Integrated Outpatient Palliative Care in Oncology Scott Shreve's comments
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | General: 1) Very impressed with the quality and depth of the analyses to include objectively assessing the strength of evidence and contacting authors for info related to integration, wow! | Thank you!
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2) Interesting that decreased mortality comes out as a key finding whereas this was not found in a large recent meta-analysis (Kavalieratos et al, JAMA) | We agree this a very interesting finding of the report. Our report was focused on integrated delivery for patients with malignancy compared to the JAMA report which included a broader range of patients and interventions.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3) Identified barriers have strong face validity (cost, space and perception pall care is for end stage) | Acknowledged, thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4) Opportunities to assist in our program office expansion of integrated palliative care include 1) meaningful elements of integration, 2) standardized caregiver depression intervention, 3) development of a specific performance measure and 4) communication of value to leadership | Acknowledged, thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | More Specific: 1) I especially appreciated the 1st paragraph of the introduction about palliative care can be provided at all stages of disease and is now the standard of care | Acknowledged, thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2) I also appreciate the reference to the American College of Surgeons' Commission on Care about requiring integration of palliative care into cancer centers as this specialty has been a barrier within VHA | Acknowledged, thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3) I need to learn more about the impact of palliative care on caregivers as the findings seem mixed (none in the JAMA meta-analysis, some here and perhaps in the Cochrane review) and GEC may be embarking on a BIG initiative to support caregivers | The JAMA review (Kavalieratos 2016) used a vote counting approach and found caregiver satisfaction improved in 4 of 5 studies reporting this outcome, but QOL, mood and caregiver burden were improved in only the minority of studies. However, this review included a broader range of conditions (e.g. heart failure) and palliative care approaches (e.g., those without clear integration). The Cochrane review (Haun 2017) was restricted to early palliative care for advanced cancer and found no effect on caregiver burden and one study showing mixed effects on caregiver mood.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4) Page 7, 2nd paragraph, 2nd sentence…”All Veterans in the United States have access to palliative care…” needs to be changed to “All enrolled Veterans in the US… | This change has been made.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5) Is there strong evidence elsewhere that the more “integrated” care is according to the Integrated Practice Assessment Tool that care is improved? | This is an interesting question. To our knowledge the level of integration has been studied infrequently, and classifications such as the one we used in our study have not been evaluated previously for an association with intervention impact.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 6) Page 18, I'd be interested to know what the median intervention was for the studies (e.g., 4 outpatient visits as it was for Temel in 2010)? I also found it surprising that the Palliative Care Interventions did not specifically mention a social worker. Our program office did some analyses and found SW staffing correlated with improved family perception of the quality of care. | The median intervention was 17 weeks in those with fixed duration; 3 studies continued the intervention until death. Two of the 9 eligible intervention studies included social workers, one as a facilitator of multidisciplinary sessions and one as part of the overall palliative care team. This information has been added to the results section.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 7) Page 21, Figure 5, I'm a bit confused in the labelling of the x axis, didn't most of these studies show a benefit for palliative care whereas the axis favors the control group? | The x axis was mislabeled and has been corrected.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 8) Page 23, increased likelihood of dying at home is important as is the impact on mortality. | We agree. These findings are highlighted in the key points and discussion.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 9) Page 24, I'm a bit disheartened to see no impact from the telephone intervention trials but ask if I'm correct that telemedicine would be an entirely different intervention? Any evidence on this? | Telemedicine is defined broadly as using telecommunications technology to evaluate, diagnose and treat patients at remote locations. Only 1 of the 9 interventions studies used telephone interactions as the primary mode for delivering care. This study is identified and discussed in the results section. There is too little data to make any definitive conclusions on telemedicine as a delivery mode for palliative care
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 10) Page 24 re reduced caregiver depressive symptoms would seem to have policy implications and perhaps a more standardized use of the intervention by our palliative care teams | Acknowledged, thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 11) Page 30, I'm enticed by the comments about integration elements (suggestion that palliative and oncology teams that have interactive, routine communication and some degree of colocation) as our program office seeks to promote integration across our system | Acknowledged, thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 12) Page 35, the use of a patient decision aid is enticing as I've heard of this being used to assist in promoting advance directives but had not heard of its effectiveness in promoting palliative care among patients (food for thought as oncologist could incorporate this at time of diagnosis) | Acknowledged, thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 13) Any thoughts on why there was an impact on short term QOL but not longer term? | There were fewer studies and fewer patients in the longer term QOL. Thus statistical power was lower for effects on longer compared with short-term QOL. There also may be clinical reasons for why long-term effects were less. As patients approach the terminal portion of illness with greater symptom burden and decreased functional status, palliative care interventions may become less effective.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 14) Page 39, Performance measures were mentioned by VA leaders as needed to facilitate integrated palliative care whereas many senior VA leaders are seeking to reduce performance measures, somewhat of a conundrum. | We agree with the reviewer that there is inconsistency regarding performance measures. The need for the development of performance measures emerged as a theme by all local leaders (Bekelman et al). However, it was incorrectly written in our summary as a potential facilitator of implementation. At this time, there are no standardized performance measures for patient-centered care and outcomes, so this is considered a barrier to outpatient palliative care implementation. The results and discussion have been updated.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Some specific comments/questions to consider -p. 20 - long-term (6-12months) benefit of PC on QoL is less robust - Is a QoL benefit at 6-12 months an attainable/desirable goal? (this is also referenced in the summary on page 40); Isn't it likely that at 6-12 months, many of these patients would have significant disease progression/overall health decline/death (or alternatively a minority may have gotten over the worst of their cancer-related symptoms and be doing better)? Should we really expect a benefit at 6-12months? Maybe we would expect that more people would be referred to hospice and possibly have improved QoL from hospice if not deceased? | Regarding p. 20, we agree with the reviewer's hypothesis that long-term QOL likely does not increase as disease progresses, and symptom burden increases as end of life draws near. We have added a sentence in the results in the first paragraph under the subheading “Effects on Functional Status, Overall Symptom Burden, and Psychological Symptoms” on p. 19 noting that the finding may be expected given patients' declining health. Additionally, because there is a lack of literature examining the appropriateness of QOL measures for use with individuals who are becoming increasingly ill and nearing death, we now note this limitation of the current literature under the Heterogeneity subheading of the Limitations section on p. 42 and as an area for future research in the “Outcomes” row of Table 9 Highest Priority Evidence Gaps on p. 44.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | p. 21 Figure 5 - bottom of figure - does negative SMD really favor control? When I read this, I wondered if the wording at the bottom was accurate or if the PC/control words needed to be switched. | The x axis was mislabeled and has been corrected.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | p. 25 yes (yet?) there may be disease-specific benefits (e.g. there may be more benefit for patients with malignancies that are more likely to have high symptom burden and low life expectancy) | This is an interesting point, that patients with different malignancies and differing symptoms may experience differing effects from palliative care interventions. Because most studies enrolled patients with a range of malignancies and with 1 exception (Temel 2017) did not examine interaction effects, we are unable to evaluate this hypothesis but have raised it as an area for future research in the discussion.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | p. 30 if all trials studied (p. 30 paragraph 2) included co-location, then we aren't able to assess whether colocation itself affects the outcome, right? (If we are trying to understand whether having PC team co-located in oncology clinic improves care [possibly by making consultation easier for patient, staff, and by “normalizing” the process], wouldn't that require us to have a comparator group that does NOT have colocation?) | Regarding p. 30, the reviewer makes a great point. Because authors were only offered the option of a “yes/no” response to the question about whether the intervention was colocated in the same facility, we did not obtain data regarding degree of physical proximity (eg, same clinic vs same facility). It is possible that differences in physical proximity could have impacted the relation between the intervention and outcomes. Additionally, there was a further lack of variability in colocation because all study authors indicated that the interventions were colocated. Thus, the review did not include any study interventions that lacked colocation which could be an important comparator. These limitations and their potential impact on the findings are now explicitly addressed in the Limitations section.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | The report is well written with clear methods and procedures for analysis. The criteria for inclusion was very restrictive and thus only a few papers included but it is helpful to have details about papers excluded. | Thank you!
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | The authors did an incredible job of systematically reviewing the literature on the benefits and harms of outpatient palliative care in advanced cancer. They developed targeted research objectives, used the appropriate quantitative and qualitative methods to synthesize the literature depending on the research question and available evidence, and went above and beyond to gather the relevant information necessary to answer their research objectives. There have been multiple prior peer-review publications that broadly synthesize the evidence on the impact of specialty palliative care; the authors decided therefore appropriately targeted their search to the outpatient arena, and subsequently focused their second and third objectives on important factors that hadn't been previously explored, including the features of palliative care that provide the greatest benefit as well as the most important barriers to implementation. Appropriately, they used primarily quantitative techniques, including conducting a meta analysis, for RCTs that met their inclusion criteria for objective 1. The results are timely and important, and they are appropriately cautious about over-interpreting the findings around quality of life, healthcare utilization, and survival. For Objective 2, the investigators went as far as to contact authors to obtain important information from the Integrated Practice Assessment Tool delivered by SAMHSA to measure the degree of integration of health care services. In Objective 3, they used a combination of quantitative and qualitative techniques appropriate to their review of the literature on barriers to implementation. The figures and tables were painstakingly detailed and easy to read and understand. They also rated the quality of the evidence, and went above and beyond by making an attempt to ascertain the degree of publication bias (turns out this was not possible due to the small number of studies that met inclusion). This is overall an outstanding job of evidence based synthesis -the authors did not take a one size fits all approach to the literature. They used a wide array of detailed assessment tools for systematic review of quantitative and qualitative evidence. They used a variety of methods depending on not only the research objective but also the available literature. I have no constructive comments! | Thank you!
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Please correct the following errors in Figures 3 and 5.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Figure 3, page 20. Temel 2010, used the FACT-L, not the FACT-G | Temel 2010 reported the FACT-L and the TOI index. We used the TOI for this analysis and this is reflected in the revised figure.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Figure 5, page 21. Temel 2010, the population studied was lung not pancreatic cancer. | Thank you. The original figure misidentified the population and has now been corrected.