# APPENDIX F DEFINITIONS AND DATA USED FOR IMPACT RATING DETERMINATIONS

The table that follows contains details related to how the impact rating was determined for each study comparing integrated palliative and oncology care interventions to a comparator or control. Table cells show what was measured, the timepoint of measurement, and an indication of the effect size. All comparisons are in the direction of intervention versus control. For full study citations, please refer to the report's main reference list.

Definitions of the impact ratings:

- High—Pattern of positive effects across all patient-centered outcomes; may also have positive effects on end-of-life care and/or utilization. Magnitude of effects include at least 1 primary outcome with summary or median SMD/effect size of 0.8 or greater; mean difference that substantially exceeds the minimum clinically important difference; or risk ratio (RR) or hazard ratio (HR) ≥2 or odds ratio (OR) ≥3.
- Moderate—Pattern of mostly positive effects across patient-centered outcomes; may also have positive effects on end-of-life care and/or utilization. Magnitude of effects include at least 1 primary outcome with summary or median SMD/effect size of ≥0.5; mean difference that meets or exceeds the minimum clinically important difference; or RR or HR ≥1.5 or OR ≥2.
- Low—Inconsistent pattern of statistically positive and negative effects across patient-centered outcomes; may also have inconsistent effects on end-of-life care and/or utilization. Magnitude of effects include at least 1 primary outcome with summary or median SMD/effect size of ≥0.25; mean difference that is statistically significant but does not meet the minimum clinically important difference; or RR or HR ≥1.25 or OR ≥1.5.
- No impact—Pattern of statistically nonsignificant effects or inconsistent pattern of statistically positive and negative effects but all patient centered outcomes are statistically nonsignificant.

Study | QOL | Symptom Burden | Mortality | Site of Death | End-of-Life Treatment | HC Utilization | Final Impact Rating
Bakitas, 2009^12^ | [underlined: At 13 months] FACT-PC mean difference: 4.6 (SE 2.0), p=0.02 | [underlined: At 13 months] CES-D mean difference: -1.8 (SE 0.81), p=0.02 ESAS mean difference: -27.8 (SE 15), p=0.06 | Survival at longest follow-up: 49/16 vs 42/161, p=0.14 Median survival time: 14 months vs 8.5 months, p=NR | NR | NR | [underlined: At 13 months] Hospital days (range 0 to 25), p=0.14 ICU days (range 0 to 2), p>0.99 ER visits (range 0 to 4), p=0.53 | Moderate
Bakitas, 2015^41^ | [underlined: At 3 months] TOI Cohen's d: 0.11, p=0.24 [underlined: At 12 months] Cohen's d: 0.11, p=0.24; | [underlined: At 3 months] QUAL-E Cohen's d: -0.21, CES-D Cohen's d: 0.04, [underlined: At 12 months] QUAL-E Cohen's d: -0.31, CES-D Cohen's d: 0.1, [underlined: Significance] over all timepoints (3,6,9,12)-QUAL-E, p=0.09 CES-D, p=0.33 | 1 year survival rate: 66/104 vs 49/103, p=0.038 Average length of survival: 18.3 vs 11.8 months | Died at home: 27/50 vs 28/59, p=0.60 | In decedents, chemotherapy during last 2 weeks of life measured at end of study RR=1.57 (95% CI 0.37 to 6.7) | In decedents, hospital days at end of study: RR=0.73 (95% CI 0.41 to 1.27), p=0.26 ICU days at end of study: RR=0.68 (95% CI 0.23 to 2.02), p=0.49 ED visits at end of study: RR=0.73 (95% CI 0.45 to 1.19), p=0.21 | Low
Clark, 2013^43^ | [underlined: At 4 weeks] FACT-G mean difference: 5.5 (no SD), p=0.02 [underlined: At 27 weeks] mean difference: 0.1, p=0.88 | [underlined: Exact timepoints unknown] POMS: p=NS FACT Spiritual Well-being Scale: p=NS | NR | NR | NR | NR | Low
Maltoni, 2016^39^ | [underlined: At 12±3 weeks] TOI mean difference: 6.3 (95% CI 0.75 to 11.95) | [underlined: Overall] HCS mean difference: 3.78 (95% CI 0.86 to 6.71), p=0.008 [underlined: At 12±3 weeks] HADS-A: p=0.06 HADS-D: p=0.28, NS | Survival probability at study end: 22.4% vs 12.3%, NS | At home vs hospice: p=0.138, NS At nursing home: p=0.702, NS | Chemotherapy last 30 days: p=0.192, NS Admission 30 days before death: p=0.539, NS ER visits 30 days before death: p=0.729, NS | Primary care visits at 12±3 weeks and at study end: p=0.0001 Hospitalizations, timeframe unclear: p=0.417, NS ER visits to study end: p=0.891, NS | Low
McCorkle, 2015^40^ | [underlined: At 3 months] FACT-G: p=0.371 | [underlined: At 3 months] SDS: p=0.610 for time*group HADS-A: p=0.1173 PHQ-9: p=0.927 for time*group | NR | NR | NR | NR | None
Rummans, 2006^44^ | [underlined: At 4 weeks] Spitzer Uniscale mean difference: 8.7 (no SD), p=0.047, % of people improved by 8 points, p=0.025 [underlined: At 27 weeks] mean difference: 0, p>.99, improved by 8 points NR | [underlined: At 4 weeks] SDS: p=NS POMS: p=NS FACIT-SP mean difference: 9, p=0.003 | NR | NR | NR | NR | Low
Temel, 2010^14^ | [underlined: At 12 weeks] TOI mean difference: 6.0 (95% CI 1.5 to 10.4), Cohen's d 0.52, p=0.009 FACT-L: mean difference 6.5 (95% CI 0.5 to 12.4), Cohen's d 0.42, p=0.03 | [underlined: At 12 weeks] overall LCS mean difference: 1.7 (95% CI 0.1 to 3.2), p=0.04 Specific diagnosis, % meeting threshold- PHQ-9: p=0.04 HADS-D: p=0.0 HADS-A: p=0.66, NS | Overall median survival: 11.6 months (95% CI 6.4 to 16.9) vs 8.9 (95% CI 6.3 to 11.4), p=0.02 | [underlined: At 18 mo follow-up] Place of death (home vs other): 40/61 vs 36/66, p=0.28 | Aggressive care: 16/49 vs 30/56, p=0.05 Hospitalization (30 days before death): 18/49 vs 30/56, p=NR; Chemotherapy (last 60 days of life): 32/61 vs 47/67, p=0.05 ED (30 days before death): 11/49 vs 17/56, p=NR | Hospitalizations from enrollment to death: 36/49 vs 43/56, p=NR ED days during entire study: 26/49 vs 32/56, p=NR Cost savings mean difference: $117 ($74) | Moderate
Temel, 2017^45^ | [underlined: At 12 weeks] FACT-G mean difference: 2.40 (95% CI -0.38 to 5.18), p=0.09 [underlined: At 24 weeks] mean difference: 5.36 (95% CI 2.04 to 8.69), p=0.02 | [underlined: At 12 weeks] PHQ-9 mean difference: -0.78 (95% CI -1.76 to 0.21), p=0.12 [underlined: At 24 weeks] Mean difference: -1.17 (95% CI -2.33 to -0.01), p=0.048 | NR | NR | NR | NR | Low
Zimmermann, 2014^42^ | [underlined: At 3 months] FACIT-SP mean difference: 3.56 (95% CI, -0.27 to 7.40), p=0.07 [underlined: At 4 months] mean difference: 6.44 (95% CI, 2.13 to 10.76), p=0.006 | [underlined: At 3 months] ESAS mean difference: -1.70 (95% CI, -5.26 to 1.87), p=NS [underlined: At 4 months] mean difference: -4.41 (95% CI, -8.76 to -0.06), p=0.05 | Raw data for number of deaths: 44/228 vs 26/233, p=NR | NR | NR | NR | Low

Abbreviations: CES-D=Center for Epidemiologic Studies Depression Scale; CI=confidence interval; ED=emergency department; ER=emergency room; ESAS=Edmonton Symptom Assessment Scale; FACIT-SP=Functional Assessment of Chronic Illness Therapy-Spiritual Well-Being; FACT-G=Functional Assessment of Cancer Therapy-General; FACT-L=Functional Assessment of Cancer Therapy-Lung; HADS=Hospital Anxiety and Depression Scale; HCS=Hepatobiliary Cancer Subscale; LCS=Lung cancer subscale; NR=not reported; PHQ=Patient Health Questionnaire; POMS=Profile of Mood States; QUAL-E=Quality of life at end of life symptom impact subscale; SDS=Symptom Distress Scale; TOI=Trial Outcome Index