# APPENDIX E AUTHOR SURVEY OF INCLUDED PALLIATIVE CARE INTERVENTION ELEMENTS

Please provide your name. For each question, please answer to describe the intervention arm in the cited study

Q1. Are palliative care provider(s) and oncology provider(s) physically or virtually located in the same space?

- Yes, colocated in the same clinical space
- Yes, virtually colocated by video link or similar
- No
- Unsure

Q2. Is written or electronic information exchanged routinely between palliative and oncology clinicians? (eg, alert in medical record, faxed documents)

- Yes
- No
- Unsure

Q3. Is communication between oncology and palliative care interactive? (ie, “two way”)

- Yes
- No, exchange of information is without interactive communication
- Unsure

Q4. Do providers from palliative care and oncology communicate on a “standard and routine practice” basis to address specific patient treatment issues? Communication may be in-person, by email exchange, team meeting, or phone call conversation.

- Yes
- No
- Unsure

Q5. Do the palliative care and oncology care health providers have equal roles in decision making? Are they both involved in the approach to individual patient care?

- Yes
- No
- Unsure

Q6. Were providers involved in care in a standard way across ALL patients? (eg, do all staff use the same tools and resources, and then ensure that all patients with the same score or outcome receives the same options for treatment?)

- Yes
- No
- Unsure

Q7. Is there one joint treatment plan for cancer patients that is shared by palliative care and oncology care providers?

- Yes
- No
- Unsure