# APPENDIX D INTERVENTION ELEMENTS AND DEFINITIONS

Below are the definitions for the 8 clinical elements of palliative care interventions. The table that follows shows which elements were present in each included study. For full study citations, please refer to the report's main reference list.

- Structural and processes of care: interdisciplinary team engagement (engagement with patients or families, coordinated assessment and continuity of care across healthcare settings)
- Physical aspects of care: what is being done to decrease symptoms (assessment and pharmacological, interventional, behavioral and/or complementary treatments)
- Psychological or psychiatric aspects of care: what is being done to address mental health issues (assessment and treatment of psychological and/or psychiatric concerns for patient or caregiver)
- Social aspects of care: interdisciplinary engagement and collaboration with patients and families (identify, support or capitalize on their strengths; facilitate patient-family understanding of illness; perform social assessment including caregiving or adaptive equipment needs, or need/access to community resources)
- Spiritual, religious, and existential aspects of care: support of spiritual belief system, if present (practices or rituals for comfort/relief; this ideally involves a trained chaplain on the palliative care team)
- Cultural aspects of care: identification of and respect for cultural differences (tailored communication to literacy level and language spoken; accommodation of cultural practices and traditions)
- End of life care of patient: guidance through the dying process (information on what to expect at end of life, suggestions of coping strategies; eg, the stages of grief: denial through acceptance)
- Ethical and legal aspects of care: goals of care (discussions about impact of treatment decisions, determination of patient's decision-making capacity, advance care planning completion; eg, Do Not Resuscitate [DNR])

Study Impact Rating | Structural | Physical | Psychological | Social | Spiritual | Cultural | End of Life | Ethical/Legal
Bakitas, 2009^12^ Moderate | No | Physical symptom management; eg, self-care | Psychological symptom management; eg, problem-solving | Attention to communication and coordination of resources | No | No | Advance care planning | Decision-making about advance care planning
Bakitas, 2015^41^ Low | No | Physical symptom management; eg, self-care | Psychological symptom management; eg, problem-solving | Attention to communication and coordination of resources | Framing advanced illness challenges as personal growth opportunities | No | Life review as applies to advance care planning | Decision-making about advance care planning
Clark, 2013^43^ Low | No | Physical therapy exercises and management of health behavior, substance use, symptoms | Psychological symptom and mood management | Social needs & communication strategies | Exploration of meaning, purpose, grief, and loss | No | No | Writing advance directives
Maltoni, 2016^39^ Low | Yes, but no details | Yes, but no details | Yes, but no details | No | Yes, but no details | No | No | No
McCorkle, 2015^40^ None | Coordinated inter-disciplinary team that collaborates with other providers to teach patients and families | Physical symptom management: executing care procedures and addressing adverse events | Counseling to clarify illness experience and enhance QOL | Enhancing self-efficacy for decision-making and problem-solving about family and caregivers | No | No | No | Goals for advance care discussed
Rummans, 2006^44^ Low | No | Physical therapy exercises and discussion of healthy lifestyle | Cognitive behavioral therapy for mood; stress management and irrational thinking | Sources and use of support, communication, interpersonal relationships and coping | Explore grief, guilt, hope, purpose, meaning, rituals, beliefs, death | No | Explore end of life, death, and afterlife; other “spiritual aspects” | No
Temel, 2010^14^ Moderate | Yes, but no details | Yes, but no details | Yes, but no details | Yes, but no details | Yes, but no details | No | Yes, but no details | Yes, but no details
Temel, 2017^45^ Low | Regular palliative care appointments; oncologist could schedule extra palliative care visits; inpatient palliative care team followed if admitted | Helping to understand prognosis, treatment options; then making treatment goals, communicate care preferences | Addressed coping, depression, and anxiety | Addressed coping with family, familial understanding of illness, and family caregiver referral | Addressed spiritual coping, rituals, and belief systems | No | Discussed end-of-life care preferences and life review | Discussed advance care planning
Zimmermann, 2014^42^ Low | Multi-disciplinary assessment | Assessment of symptoms; urgent care if necessary | Assessed psychological distress | Assessed social support | No | No | No | No