# APPENDIX C EXCLUDED STUDIES

All studies listed below were reviewed in their full-text version and excluded for the reasons cited. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles. The reference list for these excluded studies follows the table.

Exclusion reason | Not English or primary study | Not population of interest | Not eligible study design | Not eligible setting | Not eligible intervention | Not eligible outcomes | Not OECD country | N<20
Study | Not English or primary study | Not population of interest | Not eligible study design | Not eligible setting | Not eligible intervention | Not eligible outcomes | Not OECD country | N<20
Abernethy, 2013^1^ | | | | | X
Acorn, 2008^2^ | | | | | X
Addington-Hall, 1992^3^ | X
Arnold, 2010^4^ | X
Bakitas, 2009^5^ | X
Barrett, 2009^6^ | | | X
Barth, 2013^7^ | | | X
Beernaert, 2014^8^ | | | | X
Begue, 2012^9^ | | | X
Blackhall, 2016^10^ | | | X
Booth, 2010^11^ | X
Borneman, 2008^12^ | | | X
Breitbart, 2012^13^ | | | | | X
Brumley, 2003^14^ | | X
Brumley, 2007^15^ | | X
Bucher, 2001^16^ | | | X
Cameron, 2004^17^ | | | X
Chambers, 2008^18^ | X
Chochinov, 2011^19^ | | | X
Critchley, 1999^20^ | | | X
Daly, 2013^21^ | | | X
Davis, 2012^22^ | X
DeSanto-Madeya, 2009^23^ | | | | X
Dionne-Odom, 2016^24^ | | X
Dionne-Odom, 2016^25^ | | | | | X
Dionne-Odom, 2016^26^ | | | X
do Carmo, 2015^27^ | | | | | X
Douglas, 2014^28^ | | | | | X
Duursma, 2011^29^ | X
Dyar, 2012^30^ | | | | | | | | X
Edwards, 2014^31^ | | | | | X
El-Jawahri, 2010^32^ | | | | | X
El-Jawahri, 2016^33^ | | X
Engelhardt, 2006^34^ | | X
Eschbach, 2014^35^ | X
Farquhar, 2014^36^ | | | | | X
Ferrell, 2015^37^ | | | X
Fischer, 2015^38^ | | X
Follwell, 2009^39^ | | | X
Fontani, 2011^40^ | | X
Geiger, 2011^41^ | | | X
Given, 2002^42^ | | | | | X
Gomes, 2013^43^ | | | X
Gomez-Batiste, 2010^44^ | | | | | X
Goodwin, 2003^45^ | | | | | X
Gray, 1987^46^ | X
Greer, 1986^47^ | X
Greer, 2012^48^ | X
Grudzen, 2014^49^ | | | | X
Grudzen, 2016^50^ | | | | X
Hainsworth, 2002^51^ | | | X
Hanks, 2002^52^ | | | | X
Hannon, 2013^53^ | X
Hannon, 2014^54^ | X
Hannon, 2015^55^ | X
Hannon, 2016^56^ | | | | | | X
Hermann, 2012^57^ | | | | | X
Higginson, 2010^58^ | | | X
Higginson, 2010^59^ | | X
Higginson, 2014^60^ | | | | | X
Hinton, 1998^61^ | | | X
Hollen, 2000^62^ | | X
Holm, 2016^63^ | | X
Holm, 2016^64^ | | | | | X
Hughes, 1992^65^ | X
Jack, 2003 ^66^ | | | | X
Jelinek, 2014^67^ | | | | X
Johnsen, 2014^68^ | | | | | | X
Johnson, 2011^69^ | | | X
Jones, 2013^70^ | | | | X
Jordhøy, 2000^71^ | | | | | X
Jordhoy, 2001^72^ | | | | | X
Jung, 2013^73^ | | | X
Kandarian, 2014^74^ | | | | | | X
Kane, 1984^75^ | X
Keating, 2010^76^ | | | X
Kissane, 2016^77^ | | | | | X
Kotzsch, 2015^78^ | | | X
Lau, 2012^79^ | X
Lazenby, 2010^80^ | X
Lidstone, 2003^81^ | | | X
Lowe, 2009^82^ | | | X
Lowery, 2013^83^ | | | X
Lukas, 2013^84^ | | X
Maeda,2016^85^ | | | X
McCorkle, 1998^86^ | | | | | X
McDonald, 2015^87^ | X
McDonald, 2015^88^ | X
McDonald, 2016^89^ | | | | | | X
McLoughlin, 2015^90^ | X
McMillan, 2002^91^ | | | X
McMillan, 2011^92^ | | X
Mills, 2009^93^ | | | | | X
Moore, 2002^94^ | | | | | X
Morita, 2009^95^ | | X
Nabal, 2013^96^ | | | X
Nakajima, 2016^97^ | | | X
Nipp, 2016^98^ | | | X
Nordly, 2014^99^ | | | | | | X
Northouse, 2005^100^ | | | | | X
Northouse, 2007^101^ | | | | | X
Northouse, 2013^102^ | | | | | X
Obel, 2014^103^ | | | X
Obermeyer, 2016^104^ | | | X
Odejide, 2014^105^ | | | | X
Oliver, 2012^106^ | X
Ornstein, 2017^107^ | | | | | X
Otsuka, 2013^108^ | | | X
Ozcelik, 2014^109^ | | | | X
Pachman, 2011^110^ | | | X
Parikh, 2013^111^ | X
Phillips, 2008^112^ | | X
Rabow, 2003^113^ | | | X
Rabow, 2003^114^ | | X
Rabow, 2004^115^ | | X
Raftery, 1996^116^ | | | | | X
Ragnarson-Tennvall, 1999 ^117^ | | | X
Raphaël, 2005^118^ | | | X
Reville, 2009^119^ | X
Schenker, 2015^120^ | | | X
Sekelja, 2010^121^ | | X
Seow, 2014^122^ | | | X
Silveira, 2011^123^ | X
Smeenk, 1998^124^ | | | | | X
Smeenk, 1998^125^ | | | | X
Sochor, 2014^126^ | X
Steel, 2016^127^ | | | | | X
Steinhauser, 2008^128^ | | | X
Stern, 2012^129^ | | X
Strasser, 2016^130^ | | | | | X
Sun, 2015^131^ | | | X
Tattersall, 2014^132^ | | | | | X
Temel, 2007^133^ | | | X
The SUPPORT Principal Investigators, 1995^134^ | | X
Thomas, 2016^135^ | X
Tuca-Rodriguez, 2012^136^ | | | X
Uitdehaag, 2014^137^ | | | | | X
Vinciguerra, 1986^138^ | X
Vinciguerra, 1986^139^ | X
Vuksanovic, 2016^140^ | | | | | X
Wang, 2011^141^ | | X
Warren, 2011^142^ | | | X
Wentlandt, 2012^143^ | | | | | X
Wilkie, 2016^144^ | | | | | X
Yennu, 2014^145^ | X
Yoong, 2012^146^ | | | | | | | | X
Yoong, 2013^147^ | | | | | | | | X
Young, 2013^148^ | | X
Zimmermann, 2010^149^ | | | X
Zimmermann, 2012^150^ | X

## REFERENCES IN APPENDIX C

1 Abernethy AP, Currow DC, Shelby-James T, . Delivery strategies to optimize resource utilization and performance status for patients with advanced life-limiting illness: results from the “palliative care trial” [ISRCTN 81117481]. J Pain Symptom Manage. 2013;45(3):488-505.23102711
2 Acorn M. In-home palliative care increased patient satisfaction and reduced use and costs of medical services. Evidence Based Nursing. 2008;11(1):22-22.18192527
3 Addington-Hall JM, MacDonald LD, Anderson HR, . Randomised controlled trial of effects of coordinating care for terminally ill cancer patients. BMJ. 1992;305(6865):1317-1322.1483075
4 Arnold B. 2010 - Early palliative care improved quality of life in patients with newly diagnosed metastatic NSCLC. ACP J Club. 2010;153(6):2-2.
5 Bakitas M, Lyons KD, Hegel MT, . The project ENABLE II randomized controlled trial to improve palliative care for rural patients with advanced cancer: baseline findings, methodological challenges, and solutions. Palliat Support Care. 2009;7(1):75-86.19619377
6 Barrett M, Wheatland B, Haselby P, Larson A, Kristjanson L, Whyatt D. Palliative respite services using nursing staff reduces hospitalization of patients and improves acceptance among carers. Int J Palliat Nurs. 2009;15(8):389-395. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/960/CN-00721960/frame.html.19773703
7 Barth J, Delfino S, Kunzler A. Naturalistic study on the effectiveness of psycho-oncological interventions in cancer patients and their partners. Support Care Cancer. 2013;21(6):1587-1595.23299560
8 Beernaert K, Deliens L, De Vleminck A, . Early identification of palliative care needs by family physicians: A qualitative study of barriers and facilitators from the perspective of family physicians, community nurses, and patients. Palliat Med. 2014;28(6):480-490.24534727
9 Begue A, Overcash J, Lewis R, . Retrospective Study of Multidisciplinary Rounding on a Thoracic Surgical Oncology Unit. Clin J Oncol Nurs. 2012;16(6):E198-202.23178362
10 Blackhall LJ, Read P, Stukenborg G, . CARE Track for Advanced Cancer: Impact and Timing of an Outpatient Palliative Care Clinic. J Palliat Med. 2016;19(1):57-63.26624851
11 Booth S. Home palliative care services. Progress in Palliative Care.2010; 18(1):2-3.
12 Borneman T, Koczywas M, Cristea M, Reckamp K, Sun V, Ferrell B. An interdisciplinary care approach for integration of palliative care in lung cancer. Clin Lung Cancer. 2008;9(6):352-360.19073518
13 Breitbart W, Poppito S, Rosenfeld B, . Pilot randomized controlled trial of individual meaning-centered psychotherapy for patients with advanced cancer. J Clin Oncol. 2012;30(12):1304-1309.22370330
14 Brumley RD, Enguidanos S, Cherin DA. Effectiveness of a home-based palliative care program for end-of-life. J Palliat Med. 2003;6(5):715-724.14622451
15 Brumley R, Enguidanos S, Jamison P, . Increased satisfaction with care and lower costs: results of a randomized trial of in-home palliative care. J Am Geriatr Soc. 2007;55(7):993-1000.17608870
16 Bucher JA, Loscalzo M, Zabora J, . . Problem-solving cancer care education for patients and caregivers. Cancer Practice. 2001;9:66-70.11879281
17 Cameron JI, J. L Shin D W, Stewart aDE. A brief problem-solving intervention for family caregivers to individuals with advanced cancer. . J Psychosom Res. . 2004;2004. (57):137-143.
18 Chambers J. In-home palliative care increased patient satisfaction and reduced use and costs of medical services. Evid Based Med. 2008;13(1):19.18234927
19 Chochinov HM, Kristjanson LJ, Breitbart W, . Effect of dignity therapy on distress and end-of-life experience in terminally ill patients: a randomised controlled trial. Lancet Oncol. 2011;12(8):753-762.21741309
20 Critchley P, Jadad AR, Taniguchi A, . Are some palliative care delivery systems more effective and efficient than others? A systematic review of comparative studies. J Palliat Care. 1999;15(4):40-47.10693305
21 Daly BJ, Douglas SL, Gunzler D, Lipson AR. Clinical trial of a supportive care team for patients with advanced cancer. J Pain Symptom Manage. 2013;46(6):775-784.23523362
22 Davis MP. The emerging role of palliative medicine in the treatment of lung cancer patients. Cleve Clin J Med. 2012;79 Electronic Suppl 1: eS51-55.22614967
23 DeSanto-Madeya S, Nilsson M, Loggers ET, . Associations between United States acculturation and the end-of-life experience of caregivers of patients with advanced cancer. J Palliat Med. 2009;12(12):1143-1149.19995291
24 Dionne-Odom JN, Azuero A, Lyons K, Hull J, Bakitas M. Family caregiver grief and depression outcomes from the enable iii randomized controlled trial. J Pain Symptom Manage. 2016;51(2):362. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/507/CN-01139507/frame.html.
25 Dionne-Odom JN, Azuero A, Lyons KD, . Family caregiver depressive symptom and grief outcomes from the ENABLE III randomized controlled trial. J Pain Symptom Manage. 2016;52(3):378-385.27265814
26 Dionne-Odom JN, Hull JG, Martin MY, . Associations between advanced cancer patients' survival and family caregiver presence and burden. Cancer Med. 2016;5(5):853-862.26860217
27 do Carmo TM, Paiva BS, de Siqueira MR, . A phase II study in advanced cancer patients to evaluate the early transition to palliative care (the PREPArE trial): protocol study for a randomized controlled trial. Trials 2015;16:160.25872950
28 Douglas SL, Daly BJ. Effect of an integrated cancer support team on caregiver satisfaction with end-of-life care. Oncol Nurs Forum. 2014;41(4):E248-255.24969259
29 Duursma F, Schers HJ, Vissers KC, Hasselaar J. Study protocol: Optimization of complex palliative care at home via telemedicine. A cluster randomized controlled trial. BMC Palliat Care. 2011;10. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/239/CN-01016239/frame.html.
30 Dyar S, Lesperance M, Shannon R, Sloan J, Colon-Otero G. A nurse practitioner directed intervention improves the quality of life of patients with metastatic cancer: results of a randomized pilot study. J Palliat Med. 2012;15(8):890-895.22559906
31 Edwards SJ, Abbott R, Edwards J, . Outcomes assessment of a pharmacist-directed seamless care program in an ambulatory oncology clinic. J Pharm Pract. 2014;27(1):46-52.24065784
32 El-Jawahri A, Podgurski LM, Eichler AF, . Use of video to facilitate end-of-life discussions with patients with cancer: a randomized controlled trial. J Clin Oncol. 2010;28(2):305-310.19949010
33 El-Jawahri A, LeBlanc T, VanDusen H, . Effect of Inpatient Palliative Care on Quality of Life 2 Weeks After Hematopoietic Stem Cell Transplantation: A Randomized Clinical Trial. JAMA: Journal of the American Medical Association. 2016;316(20):2094-2103.27893130
34 Engelhardt JB, McClive-Reed KP, Toseland RW, Smith TL, Larson DG, Tobin DR. Effects of a program for coordinated care of advanced illness on patients, surrogates, and healthcare costs: a randomized trial. Am J Manag Care. 2006;12(2):93-100.16464138
35 Eschbach C, Heigener D, Nehls W, Villalobos M, Oorschot B. Early palliative care: Fourth modality in metastasic lung cancer. [German]. Onkologe. 2014;20(10):998-1002. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/566/CN-01072566/frame.html.
36 Farquhar MC, Prevost AT, McCrone P, . Is a specialist breathlessness service more effective and cost-effective for patients with advanced cancer and their carers than standard care? Findings of a mixed-method randomised controlled trial. BMC Med 2014;12:194.25358424
37 Ferrell B, Sun V, Hurria A, . Interdisciplinary Palliative Care for Patients With Lung Cancer. J Pain Symptom Manage. 2015;50(6):758-767.26296261
38 Fischer SM, Cervantes L, Fink RM, Kutner JS. Apoyo con Cariño: a pilot randomized controlled trial of a patient navigator intervention to improve palliative care outcomes for Latinos with serious illness. J Pain Symptom Manage. 2015;49(4):657-665. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/419/CN-01068419/frame.html.25240788
39 Follwell M, Burman D, Le LW, . Phase II study of an outpatient palliative care intervention in patients with metastatic cancer. J Clin Oncol. 2009;27(2):206-213.19064979
40 Fontani A, Martellucci J, Civitelli S, Tanzini G. Outcome of surgical treatment of colorectal cancer in the elderly. Updates Surg. 2011;63(4):233-237.21660617
41 Geiger S, Cnossen JA, Horster S, DiGioia D, Heinemann V, Stemmler HJ. Long-term follow-up of patients with metastatic breast cancer: results of a retrospective, single-center analysis from 2000 to 2005. Anticancer Drugs. 2011;22(9):933-939.21666437
42 Given B, Given CW, McCorkle R, . Pain and fatigue management: results of a nursing randomized clinical trial. Oncol Nurs Forum. 2002;29(6):949-956.12096292
43 Gomes B, Calanzani N, Curiale V, McCrone P, Higginson IJ. Effectiveness and cost-effectiveness of home palliative care services for adults with advanced illness and their caregivers. Cochrane Database Syst Rev 2013(6):CD007760.
44 Gomez-Batiste X, Porta-Sales J, Espinosa-Rojas J, Pascual-Lopez A, Tuca A, Rodriguez J. Effectiveness of palliative care services in symptom control of patients with advanced terminal cancer: a spanish, multicenter, prospective, quasi-experimental, pre-post study. J Pain Symptom Manage. 2010;40(5):652-660.20739143
45 Goodwin DM, Higginson IJ, Myers K, Douglas H, Normand CE. Effectiveness of palliative day care in improving pain, symptom control, and quality of life. J Pain Symptom Manage. 2003;25(3):202-212.12614955
46 Gray D, MacAdam D, Boldy D. A comparative cost analysis of terminal cancer care in home hospice patients and controls. J Chronic Dis. 1987;40(8):801-810.3110199
47 Greer DS, Mor V, Morris JN, Sherwood S, Kidder D, Birnbaum H. An alternative in terminal care: results of the National Hospice Study. J Chronic Dis. 1986;39(1):9-26.3511081
48 Greer JA, McMahon PM, Tramontano A, . Effect of early palliative care on health care costs in patients with metastatic NSCLC. J Clin Oncol. 2012;30(15 suppl. 1). http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/200/CN-01008200/frame.html.
49 Grudzen CR, Richardson LD, Kandarian B, Ortiz J, Copeli N, Morrison RS. Barriers to palliative care research for emergency department patients with advanced cancer. J Community Support Oncol. 2014;12(5):158-162.24971426
50 Grudzen CR, Richardson LD, Johnson PN, . Emergency Department-Initiated Palliative Care in Advanced Cancer: A Randomized Clinical Trial. JAMA Oncol. 2016.
51 Hainsworth JD, Meluch AA, McClurkan S, . Induction paclitaxel, carboplatin, and infusional 5-FU followed by concurrent radiation therapy and weekly paclitaxel/carboplatin in the treatment of locally advanced head and neck cancer: a phase II trial of the Minnie Pearl Cancer Research Network. Cancer J. 2002;8(4):311-321.12184409
52 Hanks GW, Robbins M, Sharp D, . The imPaCT study: a randomised controlled trial to evaluate a hospital palliative care team. Br J Cancer. 2002;87(7):733-739.12232756
53 Hannon B, Swami N, Pope A, . Patients' and caregivers' views on the timing and benefits of early palliative care: A qualitative study. J Clin Oncol. 2013;31(31 suppl. 1). http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/062/CN-01012062/frame.html.
54 Hannon B, Swami N, Pope A, Le L, Zimmermann C. Early palliative care and quality of death in patients with advanced cancer. Support Care Cancer. 2014;22(1 suppl. 1):S148-s149. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/062/CN-01010062/frame.html.
55 Hannon B, Swami N, Pope A, Zimmermann C. Strengthened relationships: Exploring the effects of an early palliative care intervention on patient-caregiver dyads. Support Care Cancer. 2015;23(1 suppl. 1):S209-s210. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/747/CN-01199747/frame.html.
56 Hannon B, Swami N, Rodin G, Pope A, Zimmermann C. Experiences of patients and caregivers with early palliative care: A qualitative study. Palliat Med 2016.
57 Hermann K, Engeser P, Szecsenyi J, Miksch A. Palliative patients cared for at home by PAMINO-trained and other GPs - health-related quality of life as measured by QLQ-C15-PAL and POS. BMC Palliat Care 2012;11:13.22909018
58 Higginson IJ, Evans CJ. What is the evidence that palliative care teams improve outcomes for cancer patients and their families? Cancer J. 2010;16(5):423-435.20890138
59 Higginson IJ, Gao W, Amesbury B, Normand C. Does a social model of hospice day care affect advanced cancer patients' use of other health and social services? A prospective quasi-experimental trial. Support Care Cancer. 2010; 18(5):627-637.19669169
60 Higginson IJ, Gomes B, Calanzani N, . Priorities for treatment, care and information if faced with serious illness: a comparative population-based survey in 7 European countries. Palliat Med. 2014;28(2):101-110.23703237
61 Hinton J. An assessment of open communication between people with terminal cancer, caring relatives, and others during home care. J Palliat Care. 1998;14(3):15-23.9770917
62 Hollen CJ, Hollen CW, Stolte K. Hospice and hospital oncology unit nurses: a comparative survey of knowledge and attitudes about cancer pain. Oncol Nurs Forum. 2000;27(10):1593-1599.11103378
63 Holm M, Arestedt K, Carlander I, . Short-term and long-term effects of a psycho-educational group intervention for family caregivers in palliative home care - results from a randomized control trial. Psychooncology. 2016; 25(7):795-802.26449934
64 Holm M, Årestedt K, Carlander I, . Short-term and long-term effects of a psycho-educational group intervention for family caregivers in palliative home care - results from a randomized control trial. Psychooncology. 2016;25(7):795-802.26449934
65 Hughes SL, Cummings J, Weaver F, Manheim L, Braun B, Conrad K. A randomized trial of the cost effectiveness of VA hospital-based home care for the terminally ill. Health Serv Res. 1992;26(6):801-817.1737710
66 Jack B, Hillier V, Williams A, Oldham J. Hospital based palliative care teams improve the symptoms of cancer patients. Palliat Med. 2003;17(6):498-502.14526882
67 Jelinek GA, Boughey M, Marck CH, . “Better pathways of care”: suggested improvements to the emergency department management of people with advanced cancer. J Palliat Care. 2014;30(2):83-89.25058985
68 Johnsen AT, Petersen MA, Gluud C, . Detailed statistical analysis plan for the Danish Palliative Care Trial (DanPaCT). Trials. 2014;15(1):376-376.25257804
69 Johnson C, Girgis A, Paul C, Currow DC, Adams J, Aranda S. Australian palliative care providers' perceptions and experiences of the barriers and facilitators to palliative care provision. Support Care Cancer. 2011;19(3):343-351.20157747
70 Jones L, Fitzgerald G, Leurent B, . Rehabilitation in advanced, progressive, recurrent cancer: a randomized controlled trial. J Pain Symptom Manage. 2013;46(3):315-325.e313.23182307
71 Jordhøy MS, Fayers P, Saltnes T, Ahlner-Elmqvist M, Jannert M, Kaasa S. A palliative-care intervention and death at home: a cluster randomised trial. Lancet. 2000;356(9233):888-893. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/116/CN-00332116/frame.html.11036893
72 Jordhoy MS, Fayers P, Loge JH, Ahlner-Elmqvist M, Kaasa S. Quality of life in palliative cancer care: results from a cluster randomized trial. J Clin Oncol. 2001;19(18):3884-3894.11559726
73 Jung H, Sinnarajah A, Enns B, . Managing brain metastases patients with and without radiotherapy: initial lessonsfrom a team-based consult service through a multidisciplinary integrated palliative oncology clinic. Support Care Cancer. 2013;21(12):3379-3386.23934224
74 Kandarian B, Morrison RS, Richardson LD, Ortiz J, Grudzen CR. Emergency department-initiated palliative care for advanced cancer patients: protocol for a pilot randomized controlled trial. Trials 2014;15:251.24962353
75 Kane RL, Wales J, Bernstein L, Leibowitz A, Kaplan S. A randomised controlled trial of hospice care. Lancet. 1984; 1(8382):890-894.6143195
76 Keating NL, Landrum MB, Lamont EB, Earle CC, Bozeman SR, McNeil BJ. End-of-life care for older cancer patients in the Veterans Health Administration versus the private sector. Cancer. 2010;116(15):3732-3739.20564065
77 Kissane DW, Zaider TI, Li Y, . Randomized Controlled Trial of Family Therapy in Advanced Cancer Continued Into Bereavement. J Clin Oncol. 2016;34(16):1921-1927.27069071
78 Kotzsch F, Stiel S, Heckel M, Ostgathe C, Klein C. Care trajectories and survival after discharge from specialized inpatient palliative care--results from an observational follow-up study. Support Care Cancer. 2015;23(3):627-634.25142704
79 Lau R, O'Connor M. Behind the rhetoric: is palliative care equitably available for all? Contemp Nurse. 2012;43(1):56-63.23343233
80 Lazenby JM, Saif MW. Palliative care from the beginning of treatment for advanced pancreatic cancer. Highlights from the “2010 ASCO Gastrointestinal Cancers Symposium”. Orlando, FL, USA. January 22-24, 2010. JOP. 2010;11(2):154-157.20208326
81 Lidstone V, Butters E, Seed PT, Sinnott C, Beynon T, Richards M. Symptoms and concerns amongst cancer outpatients: identifying the need for specialist palliative care. Palliat Med. 2003;17(7):588-595.14594149
82 Lowe SS, Watanabe SM, Baracos VE, Courneya KS. Associations between physical activity and quality of life in cancer patients receiving palliative care: a pilot survey. J Pain Symptom Manage. 2009;38(5):785-796.19775864
83 Lowery WJ, Lowery AW, Barnett JC, . Cost-effectiveness of early palliative care intervention in recurrent platinum-resistant ovarian cancer. Gynecol Oncol. 2013;130(3):426-430.23769759
84 Lukas L, Foltz C, Paxton H. Hospital outcomes for a home-based palliative medicine consulting service. J Palliat Med. 2013;16(2):179-184.23308377
85 Maeda I, Miyashita M, Yamagishi A, . Changes in Relatives' Perspectives on Quality of Death, Quality of Care, Pain Relief, and Caregiving Burden Before and After a Region-Based Palliative Care Intervention. J Pain Symptom Manage. 2016;52(5):637-645.27664834
86 McCorkle R, Hughes L, Robinson L, Levine B, Nuamah I. Nursing interventions for newly diagnosed older cancer patients facing terminal illness. J Palliat Care. 1998;14(3):39-45.9770920
87 McDonald J, Swami N, Hannon B, . Quality of life and satisfaction with care in caregivers of patients with advanced cancer: Results fromatrial of early palliative care. Support Care Cancer. 2015;23(1 suppl. 1): S206. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/748/CN-01199748/frame.html.
88 McDonald J, Swami N, Pope A, Hannon B, Zimmermann C. Exploring the complexities of caregiver quality of life: Qualitative results from a trial of early palliative care. Support Care Cancer. 2015;23(1 suppl. 1):S202. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/864/CN-01134864/frame.html.
89 McDonald J, Swami N, Hannon B, . Impact of early palliative care on caregivers of patients with advanced cancer: cluster randomised trial. Ann Oncol 2016.
90 McLoughlin K, Rhatigan J, McGilloway S, . INSPIRE (INvestigating Social and PractIcal suppoRts at the End of life): Pilot randomised trial of a community social and practical support intervention for adults with life-limiting illness. BMC Palliat Care. 2015;14:65. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/870/CN-01168870/frame.html.26603516
91 McMillan SC, Small BJ. Symptom distress and quality of life in patients with cancer newly admitted to hospice home care. Oncol Nurs Forum. 2002;29(10):1421-1428.12432413
92 McMillan SC, Small BJ, Haley WE. Improving hospice outcomes through systematic assessment: a clinical trial. Cancer Nurs. 2011;34(2):89-97.20885302
93 Mills ME, Murray LJ, Johnston BT, Cardwell C, Donnelly M. Does a patient-held quality-of-life diary benefit patients with inoperable lung cancer? J Clin Oncol. 2009;27(1):70-77.19029416
94 Moore S, Corner J, Haviland J, . Nurse led follow up and conventional medical follow up in management of patients with lung cancer: randomised trial. BMJ 2002;325(7373):1145.12433764
95 Morita T, Murata H, Kishi E, Miyashita M, Yamaguchi T, Uchitomi Y. Meaninglessness in terminally ill cancer patients: a randomized controlled study. J Pain Symptom Manage. 2009;37(4):649-658.18834700
96 Nabal M, Barcons M, Moreno R, Busquets X, Trujillano JJ, Requena A. Patients attended by palliative care teams: are they always comparable populations? Springerplus 2013;2(1):177.23646293
97 Nakajima N, Abe Y. Concurrent Specialized Palliative Care Upon Initiation of First-Line Chemotherapy for Cancer Progression: Is It Early Enough? Am J Hosp Palliat Care. 2016;33(4):340-345.25433067
98 Nipp RD, El-Jawahri A, Fishbein JN, . Factors associated with depression and anxiety symptoms in family caregivers of patients with incurable cancer. Ann Oncol. 2016;27(8):1607-1612.27177859
99 Nordly M, Benthien KS, Von Der Maase H, . The DOMUS study protocol: a randomized clinical trial of accelerated transition from oncological treatment to specialized palliative care at home. BMC Palliat Care 2014;13:44.25242890
100 Northouse L, Kershaw T, Mood D, Schafenacker A. Effects of a family intervention on the quality of life of women with recurrent breast cancer and their family caregivers. Psychooncology. 2005;14(6):478-491.15599947
101 Northouse LL, Mood DW, Schafenacker A, . Randomized clinical trial of a family intervention for prostate cancer patients and their spouses. Cancer. 2007;110(12):2809-2818.17999405
102 Northouse LL, Mood DW, Schafenacker A, . Randomized clinical trial of a brief and extensive dyadic intervention for advanced cancer patients and their family caregivers. Psychooncology. 2013;22(3):555-563.22290823
103 Obel J, Brockstein B, Marschke M, . Outpatient advance care planning for patients with metastatic cancer: a pilot quality improvement initiative. J Palliat Med. 2014;17(11):1231-1237.25343403
104 Obermeyer Z, Clarke AC, Makar M, Schuur JD, Cutler DM. Emergency Care Use and the Medicare Hospice Benefit for Individuals with Cancer with a Poor Prognosis. J Am Geriatr Soc. 2016;64(2):323-329.26805592
105 Odejide OO, Salas Coronado DY, Watts CD, Wright AA, Abel GA. End-of-life care for blood cancers: a series of focus groups with hematologic oncologists. J Oncol Pract. 2014;10(6):e396-403.25294393
106 Oliver DP, Demiris G, Wittenberg-Lyles E. The use of video technology for caregiver involvement in interdisciplinary hospice teams: Preliminary experiences from the active randomized clinical trial. J Pain Symptom Manage. 2012;43(2):331. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/996/CN-01005996/frame.html.
107 Ornstein KA, Penrod J, Schnur JB, . The Use of a Brief 5-Item Measure of Family Satisfaction as a Critical Quality Indicator in Advanced Cancer Care: A Multisite Comparison. J Palliat Med 2017.
108 Otsuka M, Koyama A, Matsuoka H, . Early palliative intervention for patients with advanced cancer. Jpn J Clin Oncol. 2013;43(8):788-794.23737605
109 Ozcelik H, Fadiloglu C, Karabulut B, Uyar M. Examining the effect of the case management model on patient results in the palliative care of patients with cancer. Am J Hosp Palliat Care. 2014;31(6):655-664.24097840
110 Pachman DR, Swetz KM, Mauck WD, . An exploratory pilot study of palliative medicine compared to anesthesia-pain consultation for pain in patients with cancer. J Support Oncol. 2011;9(3):113-119.21702403
111 Parikh RB, Kirch RA, Smith TJ, Temel JS. Early specialty palliative care--translating data in oncology into practice. N Engl J Med. 2013;369(24):2347-2351.24328469
112 Phillips JL, Davidson PM, Newton PJ, DiGiacomo M. Supporting patients and their caregivers after-hours at the end of life: the role of telephone support. J Pain Symptom Manage. 2008;36(1):11-21.18411012
113 Rabow MW, Schanche K, Petersen J, Dibble SL, McPhee SJ. Patient perceptions of an outpatient palliative care intervention: “It had been on my mind before, but I did not know how to start talking about death…”. J Pain Symptom Manage. 2003;26(5):1010-1015.14585552
114 Rabow MW, Petersen J, Schanche K, Dibble SL, McPhee SJ. The comprehensive care team: a description of a controlled trial of care at the beginning of the end of life. J Palliat Med. 2003;6(3):489-499.14509498
115 Rabow MW, Dibble SL, Pantilat SZ, McPhee SJ. The comprehensive care team: a controlled trial of outpatient palliative medicine consultation. Arch Intern Med. 2004;164(1):83-91.14718327
116 Raftery JP, Addington-Hall JM, MacDonald LD, . A randomized controlled trial of the cost-effectiveness of a district co-ordinating service for terminally ill cancer patients. Palliat Med. 1996;10(2):151-161.8800823
117 Ragnarson-Tennvall G, Wilking N. Treatment of locally advanced pancreatic carcinoma in Sweden. A health economic comparison of palliative treatment with best supportive care versus palliative treatment with gemcitabine in combination with best supportive care. Pharmacoeconomics. 1999;15(4):377-384.10537956
118 Raphaël R, Yves D, Giselle C, Magali M, Odile CM. Cancer treatment at home or in the hospital: what are the costs for French public health insurance? Findings of a comprehensive-cancer centre. Health Policy. 2005;72(2):141-148. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/645/CN-00513645/frame.html.15802149
119 Reville B, Axelrod D, Maury R. Palliative care for the cancer patient. Prim Care. 2009;36(4):781-810.19913186
120 Schenker Y, White D, Rosenzweig M, . Care management by oncology nurses to address palliative care needs: a pilot trial to assess feasibility, acceptability, and perceived effectiveness of the CONNECT intervention. J Palliat Med. 2015;18(3):232-240.25517219
121 Sekelja N, Butow PN, Tattersall MH. Bereaved cancer carers' experience of and preference for palliative care. Support Care Cancer. 2010;18(9):1219-1228.19821168
122 Seow H, Brazil K, Sussman J, . Impact of community based, specialist palliative care teams on hospitalisations and emergency department visits late in life and hospital deaths: a pooled analysis. BMJ. 2014;348:g3496.24906901
123 Silveira MJ, Given CW, Cease KB, . Cancer Carepartners: Improving patients' symptom management by engaging informal caregivers. BMC Palliat Care 2011;10:21.22117890
124 Smeenk FW, Ament AJ, van Haastregt JC, de Witte LP, Crebolder HF. Cost analysis of transmural home care for terminal cancer patients. Patient Educ Couns. 1998;35(3):201-211.9887852
125 Smeenk FW, de Witte LP, van Haastregt JC, Schipper RM, Biezemans HP, Crebolder HF. Transmural care. A new approach in the care for terminal cancer patients: its effects on re-hospitalization and quality of life. Patient Educ Couns. 1998;35(3):189-199.9887851
126 Sochor M, Slama O, Loucka M. Integration of palliative care into standard oncology practice in the Czech Republic. J Clin Oncol. 2014;32(15 suppl. 1). http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/793/CN-01009793/frame.html.
127 Steel JL, Geller DA, Kim KH, . Web-based collaborative care intervention to manage cancer-related symptoms in the palliative care setting. Cancer. 2016;122(8):1270-1282.26970434
128 Steinhauser KE, Alexander SC, Byock IR, George LK, Olsen MK, Tulsky JA. Do preparation and life completion discussions improve functioning and quality of life in seriously ill patients? Pilot randomized control trial. J Palliat Med. 2008;11(9):1234-1240.19021487
129 Stern A, Valaitis R, Weir R, Jadad AR. Use of home telehealth in palliative cancer care: a case study. J Telemed Telecare. 2012;18(5):297-300.22790013
130 Strasser F, Blum D, von Moos R, . The effect of real-time electronic monitoring of patient-reported symptoms and clinical syndromes in outpatient workflow of medical oncologists: E-MOSAIC, a multicenter cluster-randomized phase III study (SAKK 95/06). Ann Oncol. 2016;27(2):324-332.26646758
131 Sun V, Grant M, Koczywas M, . Effectiveness of an interdisciplinary palliative care intervention for family caregivers in lung cancer. Cancer (0008543X). 2015;121(20):3737-3745.
132 Tattersall M, Martin A, Devine R, . Early Contact with Palliative Care Services: A Randomized Trial in Patients with Newly Detected Incurable Metastatic Cancer. J Palliat Care Med. 2014;4(1):1-6.
133 Temel JS, Jackson VA, Billings JA, . Phase II study: integrated palliative care in newly diagnosed advanced non-small-cell lung cancer patients. J Clin Oncol. 2007;25(17):2377-2382.17557950
134 The SUPPORT Principal Investigators. A controlled trial to improve care for seriously ill hospitalized patients. The study to understand prognoses and preferences for outcomes and risks of treatments (SUPPORT). JAMA. 1995;274(20):1591-1598.7474243
135 Thomas CR, Jr Prospective, Interdisciplinary Randomized Clinical Trials for Patients With Cancer in the Emergency Department: A Step Forward for Palliative Oncology Care. JAMA Oncol 2016.
136 Tuca-Rodriguez A, Gomez-Batiste X, Espinosa-Rojas J, Martinez-Munoz M, Codorniu N, Porta-Sales J. Structure, organisation and clinical outcomes in cancer patients of hospital support teams in Spain. BMJ Support Palliat Care. 2012;2(4):356-362.
137 Uitdehaag MJ, van Putten PG, van Eijck CH, . Nurse-led follow-up at home vs. conventional medical outpatient clinic follow-up in patients with incurable upper gastrointestinal cancer: a randomized study. J Pain Symptom Manage. 2014;47(3):518-530.23880585
138 Vinciguerra V, Degnan TJ, Sciortino A, . A comparative assessment of home versus hospital comprehensive treatment for advanced cancer patients. J Clin Oncol. 1986;4(10):1521-1528.3760919
139 Vinciguerra V, Degnan TJ, Budman DR, . Comparative cost analysis of home and hospital treatment. Prog Clin Biol Res 1986;216:155-164.2425371
140 Vuksanovic D, Green HJ, Dyck M, Morrissey SA. Dignity Therapy and Life Review for Palliative Care Patients: A Randomized Controlled Trial. J Pain Symptom Manage. 2016;52(5):N.PAG.
141 Wang HM, Koong SL, Hsiao SC, Chen JS, Liu TW, Tang ST. Impact of availability of an inpatient hospice unit on the parent hospital's quality of palliative care for Taiwanese cancer decedents, 2001-2006. J Pain Symptom Manage. 2011;42(3):400-409.21458221
142 Warren JL, Barbera L, Bremner KE, . End-of-life care for lung cancer patients in the United States and Ontario. J Natl Cancer Inst. 2011;103(11):853-862.21593012
143 Wentlandt K, Burman D, Swami N, . Preparation for the end of life in patients with advanced cancer and association with communication with professional caregivers. Psychooncology. 2012;21(8):868-876.21648015
144 Wilkie DJ, Ezenwa MO, Yao Y, . Pain Intensity and Misconceptions Among Hospice Patients With Cancer and Their Caregivers: Status After 2 Decades. Am J Hosp Palliat Care 2016.
145 Yennu S, Fossella FV, Williams JL, . Outcomes of early palliative care referrals for patients with advanced lung cancer. J Clin Oncol. 2014;32(15 suppl. 1). http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/789/CN-01009789/frame.html.
146 Yoong J, Park ER, Greer JA, . Early outpatient palliative care in patients with metastatic NSCLC: A qualitative study. J Clin Oncol. 2012;30(15 suppl. 1). http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/191/CN-01008191/frame.html.
147 Yoong J, Park ER, Greer JA, . Early palliative care in advanced lung cancer: a qualitative study. JAMA Intern Med. 2013;173(4):283-290.23358690
148 Young JM, Butow PN, Walsh J, . Multicenter randomized trial of centralized nurse-led telephone-based care coordination to improve outcomes after surgical resection for colorectal cancer: the CONNECT intervention. J Clin Oncol. 2013;31(28):3585-3591.24002519
149 Zimmermann C, Burman D, Follwell M, . Predictors of symptom severity and response in patients with metastatic cancer. Am J Hosp Palliat Care. 2010;27(3):175-181.19783810
150 Zimmermann C, Swami N, Rodin G, . Cluster-randomized trial of early palliative care for patients with metastatic cancer. J Clin Oncol. 2012;30(15 suppl. 1). http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/200/CN-01028200/frame.html.