# APPENDIX B STUDY ELIGIBILITY CRITERIA

PICOTS Study Element | Inclusion Criteria | Exclusion Criteria
Population | Adults ≥18 years of age with symptomatic or advanced malignancy defined as one of the following:; - Malignancy causing symptoms such as fatigue, pain, or breathlessness, or unmet needs related to the malignancy; - Malignancy without curative treatment options; - Advanced stage (eg, stage III or IV malignancy), including statements of “late stage” or “advanced cancer” | - Patients with cancer not associated with systemic symptoms (eg, non-melanoma skin cancer); - Patients with non-cancer advanced illness; - Studies enrolling mixed samples unless the majority are enrolled because of a symptomatic or advanced malignancy
Intervention | Integrated palliative care meeting the following definition:; - An individual or multidisciplinary team of clinicians working together with a patient's oncology physician(s) and having a focus on relief of symptoms and stress of serious illness. Goal is to improve quality of life for the patient and family.; - One or more of the palliative care clinicians must have specialized training in palliative care, and the intervention must be multidimensional (ie, targeting at least the physical and psychosocial domains of quality of life).; Integration may be broad, ranging from basic collaboration at a distance (eg, information exchanged to address specific patient treatment issues) to colocated care, to fully integrated care. Studies that evaluate barriers to implementing an integrated palliative care program in a research or clinical context are included | - Standalone palliative care interventions (eg, palliative chemotherapy, palliative radiotherapy); - Palliative care services delivered by clinicians without specialized training; - Palliative care services (ie, hospice) delivered exclusively in the home (no outpatient clinic-based assessment) for the terminal stages of illness; - Palliative care consultation without longitudinal services; - Palliative care restricted to care for a single symptom (eg, opioids for dyspnea); - Palliative care intervention that targets only the caregiver
Comparators | KQ 1, KQ 2: Usual oncology care KQ 3: No comparator required for studies conducted in VA settings. For studies conducted outside of VA settings, the study must have an eligible comparator as specified for KQ 1 and KQ 2. | No eligible comparator
Outcomes | KQ 1, KQ 2:; - Care recipient primary outcomes:; ○ Functional status or healthcare quality of life, defined as overall QOL (ie, global QOL) and then further defined as functional status, including physical functioning (eg, activities of daily living), general psychological functioning (eg, psychological well-being) and social functioning (eg, social well-being); ○ Disease-related symptoms, overall symptom burden (if overall symptom burden was not reported, then include symptom assessment of fatigue, pain, or sleep); ○ Care experience; - Care recipient secondary outcomes:; ○ Survival; ○ Site of death; ○ Healthcare utilization such as emergency department, inpatient, intensive care unit days, total costs; ○ Adverse effects; - Caregiver outcomes:; ○ Care experience; ○ Caregiver burden (eg, Caregiver Strain Index), depression (eg, PHQ-9); The foregoing outcomes must be assessed using a standard instrument. KQ 3: Barriers to implementation, including workforce, stigma, financial, logistical (eg, space, communication and coordination between clinicians) | Studies that do not plan to report any included outcomes; but studies that plan to report an included outcome but give only cursory results (eg, p not significant) were included
Timing | KQ 1, KQ 2: Studies reporting outcomes at ≥28 days (approximately 1 month) following initiation of integrated palliative care intervention KQ 3: No follow-up requirement; may be cross-sectional | KQ 1, KQ 2: Studies reporting outcomes at <28 days
Setting | All KQs: Outpatient palliative care integrated with outpatient oncology services. Palliative care may be colocated or located in a separate outpatient setting. Services may be delivered in the emergency department, patient's home, by telephone, or by video. KQ 3: VA settings for any studies that address implementation barriers but were not eligible for KQ 1 or KQ 2 | Institutional settings (eg, skilled nursing facility) or interventions delivered primarily to hospitalized patients
Study design | KQ 1, KQ 2:; - Randomized controlled trials; - Cluster-randomized trials; - Nonrandomized cluster trials; - Controlled before-and-after studies with at least 2 intervention sites and 2 control sites; KQ 3: Quantitative studies (eg, surveys) and qualitative studies (eg, focus groups, key informant interviews, qualitative case studies) that address barriers to implementation related to studies eligible for KQ 1 or KQ 2 and studies addressing barriers in VA settings Study country limited to North America, Australia, New Zealand, and Western, Northern, and Southern Europe | - Case reports, case-series, cross-sectional studies, and all studies without a comparator; - Sample size <20 (ie, small pilot studies that are lower quality, prone to publication bias, and not powered to detect effects on clinically important outcomes)
Publication type | - English-language only; - Peer-reviewed articles; - Published from 1995 forward | - Non-English articles; - Abstracts only; - Letters to the editor; - Editorials; - Dissertations