# APPENDIX A SEARCH STRATEGIES

## PubMed search date (KQ 1, KQ 2): November 21, 2016

Set | Terms | Results
#1 | “Neoplasms”[Mesh] OR neoplasms[tiab] OR neoplasm[tiab] OR cancer[tiab] OR cancers[tiab] OR malignancy[tiab] OR malignant[tiab] OR carcinoma[tiab] OR carcinomas[tiab] OR blastoma[tiab] | 3312258
#2 | “Hospice and Palliative Care Nursing”[Mesh] OR “Palliative Medicine”[Mesh] OR “Palliative Care”[Mesh] OR “Terminal Care”[Mesh:NoExp] OR “Hospice Care”[Mesh] OR “Hospices”[Mesh] OR palliative[tiab] OR palliation[tiab] OR hospice[tiab] OR “end of life care”[tiab] | 100731
#3 | “Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR “Primary Health Care”[Mesh] OR “Home Care Services”[Mesh] OR “Residential Facilities”[Mesh] OR “Physicians, Primary Care”[Mesh] OR “Physicians, Family”[Mesh] OR “Outpatients”[Mesh] OR “Emergency Medical Services”[Mesh] OR ambulatory[tiab] OR primary care[tiab] OR outpatient[tiab] OR outpatients[tiab] OR clinic[tiab] OR clinics[tiab] OR home[tiab] OR community[tiab] OR “emergency department”[tiab] OR “out patient”[tiab] OR “out patients”[tiab] | 1200038
#4 | (“early palliative care”[tiab] OR “early palliative intervention*”[tiab]) | 166
#5 | (#2 AND #3) OR #4 | 16509
#6 | ((randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR “Comparative Study”[Publication Type] OR “Controlled Clinical Trial”[Publication Type] OR Nonrandom[tiab] OR non-random[tiab] OR nonrandomized[tiab] OR nonrandomized[tiab] OR nonrandomized[tiab] OR non-randomised[tiab] OR quasiexperiment*[tiab] OR quasiexperiment*[tiab] OR quasi-random*[tiab] OR quasi-random*[tiab] OR quasi-control*[tiab] OR quasicontrol*[tiab] OR (controlled[tiab] AND (trial[tiab] OR study[tiab]))) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])) | 3043573
#7 | #1 AND #5 AND #6 | 1364

## PubMed search date (KQ 3): January 19, 2017

Set | Terms | Results
#1 | Search (“Hospice and Palliative Care Nursing”[Mesh] OR “Palliative Medicine”[Mesh] OR “Palliative Care”[Mesh] OR “palliative care”[tiab]) | 53475
#2 | Search (“Hospice Care”[Mesh] OR “Hospices”[Mesh] OR hospice[tiab] OR “end of life care”[tiab]) | 19112
#3 | Search (#1 OR #2) | 65099
#4 | Search (barrier[tiab] OR barriers[tiab] OR implement[tiab] OR implementation[tiab]) | 408456
#6 | Search “Health Plan Implementation”[Mesh] | 4610
#7 | Search (#4 OR #6) | 410440
#8 | Search (veteran OR veterans) | 114612
#9 | Search (#3 AND #7) | 3068
#10 | Search (#9 AND #8) | 75