# REFERENCES

1 Ngo AL, Guiang R. Acute pain management. Boswell MV, Cole BE, editors. Weiner’s pain management: A practical guide for clinicians. 7th edition. Boca Raton. CRC Press. 2006.
2 Dix P, Sandhar B, Murdoch J, MacIntyre PA. Pain on medical wards in a district general hospital. British Journal of Anaesthesia. 2004;92(2):235-237. [pmid: 14722175].
3 Johnson L, Regaard A, Herrington N. Pain in general medical patients: an audit. Dostrovsky JO, Koltzenburg CD, editors. Proceedings of the 10th World Congress of Pain Progress in Pain Research and Management. Seattle. IASP Press. 2003;24.
4 Melotti RM, Samolsky-Dekel BG, Ricchi E, et al. Pain prevalence and predictors among inpatients in a major Italian teaching hospital. A baseline survey towards a pain free hospital. Eur J Pain. Oct. 2005;9(5):485-495. [pmid: 16139177].
5 Vallano A, Malouf J, Payrulet P, Banos JE. Prevalence of pain in adults admitted to Catalonian hospitals: a cross-sectional study. Eur J Pain. Nov. 2006;10(8):721-731. [pmid: 16413801].
6 Visentin M, Zanolin E, Trentin L, Sartori S, de Marco R. Prevalence and treatment of pain in adults admitted to Italian hospitals. Eur J Pain. Feb. 2005;9(1):61-67. [pmid: 15629876].
7 The Integrated Approach to the Management of Pain NIH Consensus Statement. National Institutes of Health. 1986.
8 Warfield CA, Kahn CH. Acute pain management. Programs in U.S. hospitals and experiences and attitudes among U.S. adults. Anesthesiology. Nov. 1995;83(5):1090-1094. [pmid: 7486160].
9 Morrison RS, Magaziner J, McLaughlin MA, et al. The impact of post-operative pain on outcomes following hip fracture. Pain. Jun. 2003;103(3):303-311. [pmid: 12791436].
10 Acute Pain Management: Operative or Medical Procedures and Trauma: Agency for Health Care Policy and Research. February. 1992. AHCPR Publication No. 92-0032.
11 Management of cancer pain: Agency for Health Care Policy and Research. February. 1992. 1994. AHCPR Publication No. 92-0032.
12 Shojania KG, Duncan BW, McDonald KM. Making Health Care Safer: A Critical Analysis of Patient Safety Practices. Agency for Healthcare Research and Quality. 2001. AHRQ Publication No 01-058.
13 Cleeland CS, Reyes-Gibby CC, Schall M, et al. Rapid improvement in pain management: the Veterans Health Administration and the institute for healthcare improvement collaborative. Clin J Pain. Sep-Oct. 2003;19(5):298-305. [pmid: 12966255].
14 Craine M, Kerns RD. Pain Management Improvement Strategies in the Veteran’s Health Administration. APS Bulletin. 2003;13(5).
15 McMillan SC, Tittle M, Hagan S, Laughlin J. Management of Pain and Pain-Related Symptoms in Hospitalized Veterans With Cancer. Cancer Nursing. 2000;23(5):327-336. [pmid: 11037952].
16 Kerns RD, Booss J, Bryan M, et al. Veterans Health Administration. National Pain Management Strategy: Update and Future Directions. APS Bulletin. 2006;16(1).
17 Australian and New Zealand College of Anaesthetists and Faculty of Pain Medicine. Acute Pain Management: Scientific Evidence. 2nd edition. Melbourne. Australian and New Zealand College of Anaesthetists. 2005.
18 Macintyre PE, Schug SA, Scott DA. Acute pain management: the evidence grows. An Australian document now has an important role in acute pain management worldwide. Medical Journal of Australia. 2006;184(3):101-2. [pmid: 16460291].
19 Merlin T, Hodgkinson B, Macintyre PE, Ludbrook G, Hiller JE. Institutional approaches to pain assessment and management (008PAI). A systematic literature review. Health Technology Assessment Database. 2003;(1).
20 ICSI Health Care Guideline: Assessment and Management of Acute Pain. 5th Edition. 2006.
21 Pain: Current Understanding of Assessment, Management, and Treatments. Joint Commission on Accreditation of Healthcare Organizations. 2001.
22 Improving the quality of pain management through measurement and action. Joint Commission on Accreditation of Healthcare Organizations. 2003.
23 Hadjistavropoulos T, Herr K, Turk DC, et al. An Interdisciplinary Expert Consensus Statement on Assessment of Pain in Older Persons. Clinical Journal of Pain. 2007;23(Supplement 1):S1-43. [pmid: 17179836].
24 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. American Journal of Preventive Medicine. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
25 Mora B, Giorni E, Dobrovits M, Barker R, Lang T, Gore C, Kober A. Transcutaneous electrical nerve stimulation: an effective treatment for pain caused by renal colic in emergency care. Journal of Urology. discussion 1741. 2006;175(5):1737-41. May. [pmid: 16600745].
26 Frasco PE, Sprung J, Trentman TL. The Impact of the Joint Commission for Accreditation of Healthcare Organizations Pain Initiative on Perioperative Opiate Consumption and Recovery Room Length of Stay. Anesth Analg. January 1, 2005. 2005;100(1):162-168. [pmid: 15616072].
27 Nelson BP, Cohen D, Lander O, Crawford N, Viccellio AW, Singer AJ. Mandated pain scales improve frequency of ED analgesic administration. American Journal of Emergency Medicine. Nov. 2004;22(7):582-585. [pmid: 15666265].
28 Luger TJ, Lederer W, Gassner M, Lockinger A, Ulmer H, Lorenz IH. Acute pain is underassessed in out-of-hospital emergencies. Academic Emergency Medicine. Jun. 2003;10(6):627-632. [pmid: 12782523].
29 Carey SJ, Turpin C, Smith J, Whatley J, Haddox D. Improving pain management in an acute care setting. The Crawford Long Hospital of Emory University experience. Orthopaedic Nursing. Jul-Aug. 1997;16(4):29-36. [pmid: 9287814].
30 Peters ML, Patijn J, Lame I. Pain Assessment in Younger and Older Pain Patients: Psychometric Properties and Patient Preference of Five Commonly Used Measures of Pain Intensity. Pain Medicine. 2007;8(7):601-610. [pmid: 17883744].
31 Morrison RS, Ahronheim JC, Morrison GR, et al. Pain and discomfort associated with common hospital procedures and experiences. Journal of Pain and Symptom Management. 1998;15(2):91-101. [pmid: 9494307].
32 Jaeschke R, Singer J, Guyatt GH. Measurement of health status. Ascertaining the minimal clinically important difference. Control Clin Trials. 1989;10(4):407-415. [pmid: 2691207].
33 Grant MD, Samson D. Special Report: Measuring and Reporting Pain Outcomes in Randomized Controlled Trials. TEC Assessment Program. 2006;21(11).
34 Vila H Jr, Smith RA, Augustyniak MJ, et al. The Efficacy and Safety of Pain Management Before and After Implementation of Hospital-Wide Pain Management Standards: Is Patient Safety Compromised by Treatment Based Solely on Numerical Pain Ratings?. Anesth. Analg. August 1, 2005. 2005;101(2):474-480. [pmid: 16037164].
35 Mularski RA, White-Chu F, Overbay D, Miller L, Asch SM, Ganzini L. Measuring Pain as the 5th Vital Sign Does Not Improve Quality of Pain Management. Journal of General Internal Medicine. 2006;21(6):607-612. [pmid: 16808744].
36 Krebs EE, Carey TS, Weinberger M. Accuracy of the Pain Numeric Rating Scale as a Screening Test in Primary Care. J Gen Intern Med. 2007;21(10):1453-1458. [pmid: 17668269].
37 Tanabe P, Buschmann M. A prospective study of ED pain management practices and the patient’s perspective. Journal of Emergency Nursing. Jun. 1999;25(3):171-177. [pmid: 10346837].
38 Blank FS, Mader TJ, Wolfe J, Keyes M, Kirschner R, Provost D. Adequacy of pain assessment and pain relief and correlation of patient satisfaction in 68 ED fast-track patients. Journal of Emergency Nursing. Aug. 2001;27(4):327-334. [pmid: 11468626].
39 Grant PS. Analgesia delivery in the ED. American Journal of Emergency Medicine. Nov. 2006;24(7):806-809. [pmid: 17098101].
40 Jones JB. Assessment of pain management skills in emergency medicine residents: the role of a pain education program. Journal of Emergency Medicine. Mar-Apr. 1999;17(2):349-354. [pmid: 10195504].
41 Kelly AM. A process approach to improving pain management in the emergency department: development and evaluation. Journal of Accident & Emergency Medicine. May. 2000;17(3):185-187. [pmid: 10819380].
42 Fosnocht DE, Swanson ER. Use of a triage pain protocol in the ED. American Journal of Emergency Medicine. Sep. 2007;25(7):791-793. [pmid: 17870483].
43 Arendts G, Fry M. Factors associated with delay to opiate analgesia in emergency departments. Journal of Pain. Sep. 2006;7(9):682-686. [pmid: 16942954].
44 Hwang U, Richardson LD, Sonuyi TO, Morrison RS. The effect of emergency department crowding on the management of pain in older adults with hip fracture. Journal of the American Geriatrics Society. Feb. 2006;54(2):270-275. [pmid: 16460378].
45 Pines JM, Hollander JE. Emergency department crowding is associated with poor care for patients with severe pain. Annals of Emergency Medicine. Jan. 2008;51(1):1-5. discussion 6–7. [pmid: 17913299].
46 Graber MA, Ely JW, Clarke S, Kurtz S, Weir R. Informed consent and general surgeons’ attitudes toward the use of pain medication in the acute abdomen. American Journal of Emergency Medicine. Mar. 1999;17(2):113-116. [pmid: 10102305].
47 Attard AR, Corlett MJ, Kidner NJ, Leslie AP, Fraser IA. Safety of early pain relief for acute abdominal pain. BMJ. 1992;305:554-556. [pmid: 1393034].
48 Pace S, Burke T. Intravenous morphine for early pain relief in patients with acute abdominal pain. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. 1996;3(12):1086-1092. [pmid: 8959160].
49 McHale PM, LoVecchio F. Narcotic analgesia in the acute abdomen--a review of prospective trials. Eur J Emerg Med. Jun. 2001;8(2):131-136. [pmid: 11436909].
50 Nissman SA, Kaplan LJ, Mann BD. Critically reappraising the literature-driven practice of analgesia administration for acute abdominal pain in the emergency room prior to surgical evaluation. American Journal of Surgery. Apr. 2003;185(4):291-296. [pmid: 12657376].
51 Ranji SR, Goldman LE, Simel DL, Shojania KG. Do opiates affect the clinical evaluation of patients with acute abdominal pain?. JAMA. Oct 11. 2006;296(14):1764-1774. [pmid: 17032990].
52 Bijur PE, Berard A, Esses D, Nestor J, Schechter C, Gallagher EJ. Lack of influence of patient self-report of pain intensity on administration of opioids for suspected long-bone fractures. Journal of Pain. Jun. 2006;7(6):438-444. [pmid: 16750800].
53 Shabbir J, Ridgway PF, Lynch K, et al. Administration of analgesia for acute abdominal pain sufferers in the accident and emergency setting. European Journal of Emergency Medicine. Dec. 2004;11(6):309-312. [pmid: 15542986].
54 Morrison RS, Meier DE, Fischberg D, et al. Improving the management of pain in hospitalized adults. Archives of Internal Medicine. May 8. 2006;166(9):1033-1039. [pmid: 16682579].
55 Goldberg GR, Morrison RS. Pain management in hospitalized cancer patients: a systematic review. J Clin Oncology. 2007;25(13):1792-1801.
56 White PF. Use of patient-controlled analgesia for management of acute pain. JAMA. Jan 8. 1988;259(2):243-247. [pmid: 3275811].
57 Fulda GJ, Giberson F, Fagraeus L. A prospective randomized trial of nebulized morphine compared with patient-controlled analgesia morphine in the management of acute thoracic pain. J Trauma. Aug. 2005;59(2):383-388. discussion 389–390. [pmid: 16294079].
58 Evans E, Turley N, Robinson N, Clancy M. Randomised controlled trial of patient controlled analgesia compared with nurse delivered analgesia in an emergency department. Emergency Medicine Journal. Jan. 2005;22(1):25-29. [pmid: 15611537].
59 Moon MR, Luchette FA, Gibson SW, et al. Prospective, randomized comparison of epidural versus parenteral opioid analgesia in thoracic trauma. Annals of Surgery. May. 1999;229(5):684-691. discussion 691–682. [pmid: 10235527].
60 Wu CL, Jani ND, Perkins FM, Barquist E. Thoracic epidural analgesia versus intravenous patient-controlled analgesia for the treatment of rib fracture pain after motor vehicle crash. J Trauma. Sep. 1999;47(3):564-567. [pmid: 10498316].
61 Liu SS, Wu CL. The Effect of Analgesic Technique on Postoperative Patient-Reported Outcomes Including Analgesia: A Systematic Review. Anesth Analg. September 1, 2007. 2007;105(3):789-808. [pmid: 17717242].
62 Liu SS, Wu CL. Effect of Postoperative Analgesia on Major Postoperative Complications: A Systematic Update of the Evidence. Anesth Analg. March 1, 2007. 2007;104(3):689-702. [pmid: 17312231].
63 Bainbridge D, Martin JE, Cheng DC. Patient-controlled versus nurse-controlled analgesia after cardiac surgery--a meta-analysis. Canadian Journal of Anaesthesia. May. 2006;53(5):492-499. [pmid: 16636035].
64 Block BM, Liu SS, Rowlingson AJ, Cowan AR, Cowan JA Jr, Wu CL. Efficacy of Postoperative Epidural Analgesia: A Meta-analysis. JAMA. November 12, 2003. 2003;290(18):2455-2463. [pmid: 14612482].
65 Walder B, Schafer M, Henzi I, Tramer MR. Efficacy and safety of patient-controlled opioid analgesia for acute postoperative pain. A quantitative systematic review. Acta Anaesthesiologica Scandinavica. Aug. 2001;45(7):795-804. [pmid: 11472277].
66 Hudcova J, McNicol E, Quah C, Lau J, Carr DB. Patient controlled opioid analgesia versus conventional opioid analgesia for postoperative pain. Cochrane Database Syst Rev. 2006;(4):CD003348.
67 Hudcova J, McNicol E, Quah C, Lau J, Carr DB. Patient controlled opioid analgesia versus conventional opioid analgesia for postoperative pain. Cochrane Database Syst Rev. 2006;(4):CD003348.
68 Tziavrangos E, Schug SA. Regional anaesthesia and perioperative outcome. Current Opinion in Anaesthesiology. Oct. 2006;19(5):521-525. [pmid: 16960485].
69 Werawatganon T, Charuluxanun S. Patient controlled intravenous opioid analgesia versus continuous epidural analgesia for pain after intra-abdominal surgery. Cochrane Database Syst Rev. 2005;(1):CD004088.
70 Werawatganon T, Charuluxanun S. Patient controlled intravenous opioid analgesia versus continuous epidural analgesia for pain after intra-abdominal surgery. Cochrane Database Syst Rev. 2005;(1):CD004088.
71 Macintyre PE. Safety and efficacy of patient-controlled analgesia. British Journal of Anaesthesia. Jul. 2001;87(1):36-46. [pmid: 11460812].
72 Hagle ME, Lehr VT, Brubakken K, Shippee A. Respiratory depression in adult patients with intravenous patient-controlled analgesia. Orthopaedic Nursing. Jan-Feb. 2004;23(1):18-27. quiz 28–19. [pmid: 14999949].
73 Ashburn MA, Love G, Pace NL. Respiratory-related critical events with intravenous patient-controlled analgesia. Clinical Journal of Pain. Mar. 1994;10(1):52-56. [pmid: 8193444].
74 Tramer MR, Williams JE, Carroll D, Wiffen PJ, Moore RA, McQuay HJ. Comparing analgesic efficacy of non-steroidal anti-inflammatory drugs given by different routes in acute and chronic pain: a qualitative systematic review. Acta Anaesthesiologica Scandinavica. Jan. 1998;42(1):71-79. [pmid: 9527748].
75 Nelson CE, Nylander C, Olsson AM, Olsson R, Pettersson BA, Wallstrom I. Rectal v. intravenous administration of indomethacin in the treatment of renal colic. Acta Chirurgica Scandinavica. Apr. 1988;154(4):253-255. [pmid: 3287813].
76 Nissen I, Birke H, Olsen JB, et al. Treatment of ureteric colic. Intravenous versus rectal administration of indomethacin. British Journal of Urology. Jun. 1990;65(6):576-579. [pmid: 2196971].
77 Muriel-Villoria C, Zungri-Telo E, Diaz-Curiel M, et al. Comparison of the onset and duration of the analgesic effect of dipyrone, 1 or 2 g, by the intramuscular or intravenous route, in acute renal colic. European Journal of Clinical Pharmacology. 1995;48(2):103-107. [pmid: 7589022].
78 Holdgate A, Pollock T. Nonsteroidal anti-inflammatory drugs (NSAIDS) versus opioids for acute renal colic. Cochrane Database Syst Rev. 2005;(2):CD004137.
79 Quigley C. Hydromorphone for acute and chronic pain. Cochrane Database Syst Rev. 2002;(1):CD003447.
80 Jasani NB, O’Conner RE, Bouzoukis JK. Comparison of hydromorphone and meperidine for ureteral colic. Academic Emergency Medicine. Nov-Dec. 1994;1(6):539-543. [pmid: 7541310].
81 Uden P, Starck CJ, Berger T. Comparison of indomethacin and dihydromorphinone in acute, biliary stone pain. Current Ther Res. 1984;36(6):1228-1234.
82 Halbert J, Crotty M. Evidence for the optimal management of acute and chronic phantom pain: a systematic review. Clin J Pain. 2002;18(2):84-92. [pmid: 11882771].
83 Sherman RA, Sherman CJ, Gall NG. A survey of current phantom limb pain treatment in the United States. Pain. 1980;8:85-99. [pmid: 6988765].
84 Jaeger H, Maier C. Calcitonin in phantom limb pain: a double-blind study. Pain. Jan. 1992;48(1):21-27. [pmid: 1738570].
85 Nikolajsen L, Hansen CL, Nielsen J, Keller J, Arendt-Nielsen L, Jensen TS. The effect of ketamine on phantom pain: a central neuropathic disorder maintained by peripheral input. Pain. Sep. 1996;67(1):69-77. [pmid: 8895233].
86 Huse E, Larbig W, Flor H, Birbaumer N. The effect of opioids on phantom limb pain and cortical reorganization. Pain. Feb 1. 2001;90(1–2):47-55. [pmid: 11166969].
87 Wu CL, Tella P, Staats PS, et al. Analgesic effects of intravenous lidocaine and morphine on postamputation pain: a randomized double-blind, active placebo-controlled, crossover trial. Anesthesiology. Apr. 2002;96(4):841-848. [pmid: 11964590].
88 Bone M, Critchley P, Buggy DJ. Gabapentin in postamputation phantom limb pain: a randomized, double-blind, placebo-controlled, cross-over study. Regional Anesthesia & Pain Medicine. Sep-Oct. 2002;27(5):481-486. [pmid: 12373695].
89 Dertwinkel R, Henrichs C, Senne I, et al. Prevention of severe phantom limb pain by perioperative administration of ketamine - an observational study. Acute Pain. 2002;4:9-13.
90 Hayes C, Armstrong-Brown A, Burstal R. Perioperative intravenous ketamine infusion for the prevention of persistent post-amputation pain: a randomized, controlled trial. Anaesthesia & Intensive Care. Jun. 2004;32(3):330-338. [pmid: 15264726].
91 Gehling M, Tryba M. [Prophylaxis of phantom pain: is regional analgesia ineffective?]. Schmerz. Jan. 2003;17(1):11-19. [pmid: 12579385].
92 Flor H, Denke C, Schaefer M, Grusser S. Effect of sensory discrimination training on cortical reorganisation and phantom limb pain. Lancet. Jun 2. 2001;357(9270):1763-1764. [pmid: 11403816].
93 Cook AK, Niven CA, Downs MG. Assessing the pain of people with cognitive impairment. International Journal of Geriatric Psychiatry. Jun. 1999;14(6):421-425. [pmid: 10398350].
94 Weiner D, Peterson B, Ladd K, McConnell E, Keefe F. Pain in nursing home residents: An exploration of prevalence, staff perspectives, and practical aspects of measurement. Clin J Pain. 1999;15(2):92-101. [pmid: 10382922].
95 Parmelee P. Pain complaints and cognitive status among elderly institution residents. Journal of the American Geriatrics Society. 1993;41(5):517-522. [pmid: 8486885].
96 Pautex S, Michon A, Guedira M, et al. Pain in severe dementia: self-assessment or observational scales?. Journal of the American Geriatrics Society. 2006;54(7):1040-1045. [pmid: 16866673].
97 Buffum MD, Hutt E, Chang VT, Craine MH, Snow AL. Cognitive impairment and pain management: Review of issues and challenges. Journal of Rehabilitation Research & Development. 2007;44(2):315-330. [pmid: 17551882].
98 Assessing Pain in the Patient with Impaired Communication: A Consensus Statement from the VHA National Pain Management Strategy Coordinating Committee. Affairs V, editor. 2004.
99 Pautex S, Herrmann F, Le Lous P, Fabjan M, Michel JP, Gold G. Feasibility and reliability of four pain self-assessment scales and correlation with an observational rating scale in hospitalized elderly demented patients. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Apr. 2005;60(4):524-529.
100 Defrin R, Lotan M, Pick CG. The evaluation of acute pain in individuals with cognitive impairment: a differential effect of the level of impairment. Pain. Oct. 2006;124(3):312-320. [pmid: 16781070].
101 Chibnall JT, Tait RC. Pain assessment in cognitively impaired and unimpaired older adults: a comparison of four scales. Pain. May. 2001;92(1–2):173-186. [pmid: 11323138].
102 Herr K, Bjoro K, Decker S. Tools for assessment of pain in nonverbal older adults with dementia: a state-of-the-science review. Journal of Pain & Symptom Management. Feb. 2006;31(2):170-192. [pmid: 16488350].
103 van Herk R, van Dijk M, Baar FP, Tibboel D, de Wit R. Observation scales for pain assessment in older adults with cognitive impairments or communication difficulties. Nurs Res. 2007;56(1):34-43. [pmid: 17179872].
104 Zwakhalen SMG, Hamers JPH, Abu-Saad HH, Berger MPF. Pain in elderly people with severe dementia: a systematic review of behavioural pain assessment tools. BMC Geriatrics. 2006;6:3. [pmid: 16441889].
105 Definitions Related to the Use of Opioids for the Treatment of Pain. http://www.ampainsoc.org/advocacy/opioids2.htm. Accessed December 10, 2007. 2007.
106 Savage SR, Joranson DE, Covington EC, Schnoll SH, Heit HA, Gilson AM. Definitions related to the medical use of opioids: evolution towards universal agreement. J Pain Symptom Manage. 2003;26:655-667. [pmid: 12850648].
107 Hojsted J, Sjogren P. Addiction to opioids in chronic pain patients: A literature review. European Journal of Pain. 2007;11(5):490-518. [pmid: 17070082].
108 American Medical Directors Association. We care: tool kit for implementation of the clinical practice guideline for pain management. Columbia (MD). American Medical Directors Association (AMDA). 2004.
109 ACOVE quality indicators. Assessing the Care of Vulnerable Elders Project. Rand Health. Santa Monica, California. Chodosh J, Ferrell BA, Shekelle PG, et al. Quality indicators for pain management in vulnerable elders. Ann Intern Med. 2001;135:641-758. [pmid: 11601945].
110 Agency for Healthcare Research and Quality (AHRQ). CAHPS hospital survey. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Feb. 1. 2006:4. Centers for Medicare & Medicaid Services (CMS). HCAHPS survey [http://www.hcahpsonline.org] Baltimore (MD): Centers for Medicare & Medicaid Services (CMS).