# METHODS

## Topic Development

This project was nominated by Robert Kerns, Ph.D, VA National Coordinator for Pain Management, with input from a technical expert panel. Dr. Kerns proposed that we integrate the existing literature on the delivery of effective pain care in the acute inpatient medical ward. The results will be used to inform the VA’s National Pain Management Strategy.

Key questions were discussed and finalized during a conference call that included the Steering Committee of the Evidence Synthesis Project and the Portland VAMC project site director. The questions apply only to the target population of inpatients on medical and neurology wards, not to surgical patients, patients with cancer, or patients with sickle cell crisis.

The final key questions are:

1. For inpatients who have acute pain, how do differences in timing and frequency of assessment, severity of pain, and follow-up of pain affect choice of treatment, clinical outcomes, and safety?
2. How do the timing and route of administration of pain interventions compare in effectiveness, adverse effects, and safety in these inpatient care settings?
3. For inpatients with impaired self-report due to any of several factors, including delirium or confusion, pre-existing severe dementia, closed head injury, stroke, and psychosis, how do differences in assessment and management of acute pain affect clinical outcomes or safety?
4. For inpatients with dependencies on tobacco, alcohol, stimulant, marijuana, or opioids, how do differences in assessment and management of acute pain affect clinical outcomes or safety? How do the assessment and management of acute pain differ between patients on prexisting opioid therapy and patients with opiate addiction?

We developed an analytic framework (Figure 1) to depict the clinical logic underlying these questions and the rationale for study selection. Figure 1 shows the relationship between pain assessment and improved pain outcomes. For Key Question 1, we sought direct evidence linking improved pain assessment to improvements in pain outcomes (Arrow 1a), earlier or better treatment (Arrow 1b), or better detection and monitoring (Arrow 1c). Interventions to improve pain assessment could include a better choice of pain measure or different protocols for the frequency and timing of assessment.

Figure 1 Analytic Framework Showing Relationships among Key Questions

Most interventions to improve pain assessment are part of broader systemwide programs that combine strategies to improve the timeliness and frequency of assessment with strategies to increase awareness and responsiveness to pain. When it comes to assessing effects on treatment and pain outcomes, the components aimed at assessment cannot be separated from other components, such as acute pain management teams. We discuss these interventions in the section about Key Question 2.

For Key Question 2, we assessed the timing and route of administration of therapy affect outcomes. At a system level, systemwide programs, acute pain management services, preprinted orders, clinical algorithms, and other management interventions may affect the timing and route of administration of pain treatments. At a more clinical level, we evaluated the use of intravenous versus other routes, prn orders, and patient-controlled analgesia.

Key Questions 3 and 4 follow the logic depicted in Figure 1, applied to patients with cognitive impairment and substance abuse problems, respectively.

## Search Strategy

Initially, we searched for previous systematic reviews in Medline, PubMed Clinical Queries, and the Cochrane Database of Systematic Reviews (1996 to April, 2007.) We identified several previous reviews:

Acute Pain Management: Scientific Evidence, 2^nd^ edition (2005)17. The ANZCA review and guideline covers scientific articles published after 1998; it does not specify the closing date of the searches. ANZCA is agood-quality systematic review and guideline from Australia that provides the best available summary of research findings and recommendations for future research for many of the questions addressed in our report.17 The guideline covers post-operative pain as well as acute pain associated with non-surgical conditions such as spinal cord injury, burns, cancer, acute zoster, neurological diseases, haematological disorders (e.g. sickle cell disease) and HIV/AIDS, as well as abdominal (e.g. renal and biliary colic), cardiac, musculoskeletal and orofacial pain and headache. It also covered acute pain management in the elderly, opioid-tolerant patients, patients with obstructive sleep apnea, renal or hepatic impairment or asubstance abuse disorder.18

Institutional Approaches to Pain Assessment and Management (2003). This National Institute of Clinical Studies Literature Review, also from Australia, covers literature published between 1995 and May, 2002.^19^ This systematic review covers multi-level institutional strategies, Acute Pain Services, and other dedicated-service strategies to improve pain assessment and management.

ICSI Healthcare Guideline: Assessment and Management of Acute Pain, 5^th^ ed. 2006. This guideline provides algorithms for managing acute somatic, visceral, and neuropathic pain. It cites some pertinent articles published 2005 or before, and suggests some performance measures, 20 but is not based on a systematic review.

Pain: Current Understanding of Assessment, Management, and Treatments (2001) 21 and Improving the quality of pain management through measurement and action (2003),22 address the application of continuous quality improvement techniques to pain assessment and management and the implementation of performance measurement processes. Both reports were prepared by the National Pharmaceutical Forum in collaboration with JCAHO.

International Association for the Study of Pain consensus guidelines on assessing pain in the elderly (2007) 23 While not evidence-based, these guidelines cite a large body of evidence about different approaches to assessing pain and includes a section about assessing pain in patients with cognitive impairment.

We proceeded to conduct a targeted search in Medline for primary research studies published from 1950 to July 2007 that address KQ1 or KQ2, the use of PCA for non-surgical pain. A list of studies included in the previous reviews, as well as the search terms and MeSH headings for the various search strategies, are found in Appendix A.

## Study Selection

Two reviewers assessed for relevance the abstracts of citations identified from literature searches, using the criteria described in Appendix B. Full-text articles of potentially relevant abstracts were retrieved and a second review for inclusion was conducted by reapplying the inclusion criteria. Eligible articles had English-language abstracts and provided primary data relevant to the key questions. We included studies that were conducted in inpatients with acute pain and reported data on any of the following: Association between timing and frequency of pain assessment, severity of pain, and choice of treatment (e.g. regional blocks, medications, or other therapies); method of pain assessment (e.g. 11-point pain scale, visual analog scale, verbal descriptor scale; timing and route of administration of pain interventions (e.g. oral intermittent pharmacotherapy, intravenous therapy, psychological interventions, positioning, neural blockade, and patient-controlled analgesia); timeliness of enactment of treatment plans, changes in treatment plans; effect of coordination of care with the patient’s primary care physician or with a pain consultation service on choice of treatment, clinical outcomes, and safety; patient outcomes, including degree of pain relief, pain intensity, emotional well-being, patient satisfaction, physical function, and fitness for rehabilitation of the underlying condition; safety outcomes; severity and frequency of side effects (including somnolence, respiratory depression, confusion, constipation, ileus, vomiting, non-allergic itching, weakness/numbness, and use of naloxone); length of stay; or follow-up of pain. We excluded studies of interventions that were not routinely available in the VA health system. We excluded studies of post-operative pain, sickle cell disease, cancer pain, chronic pain in patients hospitalized 10 days or longer for whom pain is chronic or refractory, except when studies of adverse effects were not available in the target population.

## Data Abstraction and Quality Assessment

We abstracted the following data from included studies: Study Design/setting, Objective, eligibility criteria/method for assembling cohort, exclusion criteria, sample size, years of enrollment/observation, duration of follow-up, demographics, clinical category/baseline pain, method used to assess pain, intervention/exposure of interest, outcomes measured, potential confounders considered, results, conclusions. Although the studies were heterogeneous in design, objectives, and outcomes, we rated the quality of evidence of studies when applicable, using the criteria of the U.S. Preventive Services Task Force for evaluating randomized controlled trials and cohort and studies (Appendix C).24 For example, for randomized trials, we abstracted data on treatment allocation; \ the method of randomization; concealment of treatment allocation; similarity of groups at baseline regarding the most important prognostic indicators; blinding of the outcome assessor, care provider; and patients; loss to followup and use of intention-to-treat analysis.

## Data Synthesis

We constructed evidence tables showing the study characteristics and results for all included studies, organized by key question, intervention, or clinical condition, as appropriate. We critically analyzed studies to compare their characteristics, methods, and findings. We compiled a summary of findings for each key question or clinical topic, and drew conclusions based on qualitative synthesis of the findings.

## Rating the body of evidence

We assessed the overall quality of evidence for outcomes using a method developed by the Grade Working Group, which classified the grade of evidence across outcomes according to the following criteria:

- ○ High = Further research is very unlikely to change our confidence on the estimate of effect.
- ○ Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- ○ Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- ○ Very Low = Any estimate of effect is very uncertain.

GRADE also suggests using the following scheme for assigning the “grade” or strength of evidence:

Criteria for assigning grade of evidence

Type of evidence

Randomized trial = high

Observational study = low

Any other evidence = very low

Decrease grade if:

- Serious (−1) or very serious (−2) limitation to study quality
- Important inconsistency (−1)
- Some (−1) or major (−2) uncertainty about directness
- Imprecise or sparse data (−1)
- High probability of reporting bias (−1)

Increase grade if:

- Strong evidence of association-significant relative risk of > 2 (< 0.5) based on consistent evidence from two or more observational studies, with no plausible confounders (+1)
- Very strong evidence of association-significant relative risk of > 5 (< 0.2) based on direct evidence with no major threats to validity (+2)
- Evidence of a dose response gradient (+1)
- All plausible confounders would have reduced the effect (+1)

For this report, we used both this explicit scoring scheme and the global implicit judgment about “confidence” in the result.

## Peer Review

Four peer reviewers provided feedback on the draft version of this report. Their comments and our responses are presented in Appendix D. One peer reviewer identified a potentially relevant article25 and criticized the search strategy. In response, we conducted supplemental searches that identified 76 citations, two of which proved relevant to this report. The remaining citations concerned surgical, trauma, prehospital, emergency, and chronic patient settings.