# CONCLUSIONS

## Summary of evidence by key question

The results of the systematic evidence review, including the type and quality of evidence for each key question, are summarized in Table 5.

Table 5 Summary of Systematic Evidence Review, by Key Question

Key Question 1. How do differences in timing and frequency of assessment, severity of pain, and follow-up of pain affect choice of treatment, clinical outcomes, and safety?
KQ# | Key question | Type of Evidence | Grade of Evidence | Comments
1a | In medical inpatients with acute pain, does routine assessment of pain affect choice of treatment, clinical outcomes, and safety? | None | GRADE Very Low = Any estimate of effect is very uncertain. | We found no evidence that directly linked the timing, frequency, or choice of measure for assessment with the timeliness, choice, or safety of treatment specifically in medical inpatients. Older studies demonstrated that observational assessment of pain by a nurse or physician is inaccurate.
1b | Does the choice of assessment measure affect choice of treatment, clinical outcomes, and safety? | 1 descriptive study in cancer patients | GRADE Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate. | Within a program of routine assessment of pain, we found no studies of how the choice of assessment measure affects the choice of treatment, clinical outcomes, or safety. Most studies focus on the psychometric qualities and ease of administration of each method. In cancer patients, there is fair evidence from one observational study that opioid-related oversedation and other adverse effects increased substantially after implementation of pain assessment on a numerical scale routinely with other vital signs.
1c | Do protocols for assessing pain improve outcomes? | None | Very Low | In most cases, these protocols are part of larger, institution-wide strategies to improve pain management. We found no evaluations that could isolate the effect of algorithms, preprinted orders, clinical pathways, or other protocols for assessing pain in the target population.
1d | Are there gaps in quality even when pain is assessed routinely? | 5 descriptive studies in the ED | GRADE Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate. | 3 chart review studies in the ED setting found that gaps in quality that remain after institution of system changes. Having a lower-priority triage score, older age, and diagnostic uncertainty were factors associated with delay or lower likelihood of receiving analgesia. In a study of patients with acute abdomen in an ED with direct access to on-call surgical service, females, less severe pain, and daytime admissions predicted delays in analgesia, despite the elimination of referral delay.
1e | Specific condition: nonsurgical abdominal pain | 1 systematic review and meta-analysis of randomized trials and 1 additional trial | GRADE High = Further research is very unlikely to change our confidence on the estimate of effect. | Opioid administration has a negligible impact on clinical management of acute abdominal pain.

Key Question 2. How do the timing and route of administration of pain interventions compare in effectiveness, adverse effects, and safety in inpatient care
KQ# | Key question | Type of Evidence | Grade of Evidence | Comments
2a | Do acute pain management teams and other institutional initiatives improve effectiveness, adverse effects, and safety in medical inpatients? | 1 uncontrolled systemwide intervention and 1 controlled trial | Moderate | 1 uncontrolled collaborative VHA/IHI study of institution-wide strategies showed measurable improvements in the prevalence of severe pain, frequency of assessment and documentation of plan of care, and provision of patient education on pain management. A controlled trial of a multifaceted intervention achieved increased assessment of pain but did not alter pain intensity or duration.
2b | Do acute pain management teams and other institutional initiatives improve effectiveness, adverse effects, and safety in other settings? | 2 systematic reviews of before-after or uncontrolled studies | Low | Most primary studies in these reviews were in postoperative or cancer pain, and were uncontrolled. While pain management teams and other system-wide interventions improved the timeliness and frequency of pain assessment, the findings were mixed for improvement in pain outcomes. In controlled studies, Acute Pain Services reduced pain intensity and improved functional ability, although the magnitude of these effects was not always clinically important.
2c | How does coordination with the patient’s primary care physician affect outcomes? | None | Very Low | We found no evidence about the value of coordinating care with the patient’s primary care physician.
2d | How does the choice of treatment modality affect effectiveness, adverse effects, and safety in inpatient care settings? | None | Very Low | We found no evidence on the comparative effectiveness of different agents and methods of administration in general inpatients.
2e | Effectiveness and safety of patient-controlled analgesia (PCA) | 3 controlled trials and 1 cohort study | Low | There is almost no information on the use or safety of PCA in a medical ward setting. Most of the evidence on the adverse effects of PCA was derived from the experience of patients with postoperative or chronic conditions.
2e | Specific conditions: renal colic and biliary stone pain | Renal colic studies: 3 RCTs comparing route of NSAID administration; 1 systematic review of NSAIDS vs. opioids; 1 RCT of hydromorphone; 1 study of hydromorphone in biliary pain | Moderate | (1) NSAIDs provide effective analgesia for acute renal colic, and act more quickly through the IV route than by IM or PR 2) Opioids provide analgesia that is equivalent to NSAIDs but result in a higher incidence of vomiting and other adverse events, particularly pethidine 3) Hydromorphone provided superior pain relief and led to fewer hospital admissions compared with meperidine in one study. Many studies excluded patients who had negative followup investigations for biliary stone or renal calculi, which may limit the applicability of findings to all patients presenting with pain from these suspected causes.
2g | Specific conditions: phantom limb pain | 1 systematic review of controlled trials | Low | Overall there is a paucity of evidence to guide specific specific treatment of phantom limb pain. The evidence on preemptive epidurals, early regional nerve blocks, and mechanical vibratory stimulation provides inconsistent support for these treatments. Single studies showed evidence of the effectiveness of various therapies (calcitonin, morphine, ketamine, gabapentin, and sensory discrimination training), and perioperative studies of ketamine and epidural analgesia showed reduced incidence of phantom limb pain, but these studies were limited by small sample size.

Key Questions 3 and 4
KQ# | Key question | Type of Evidence | Grade of Evidence | Comments
3 | For inpatients with impaired self-report due to any of several factors, including delirium or confusion, pre- existing severe dementia, closed head injury, stroke, and psychosis, how do differences in assessment and management of acute pain affect clinical outcomes or safety? | 3 systematic reviews of descriptive and cross-sectional evaluations of assessment instruments; no study designs were excluded | Low | Most studies were conducted in nursing homes in patients with dementia, and focused on assessment. Delirium is a more common cause of cognitive impairment in the medical inpatient setting, and we identified no studies of pain assessment or management in patients with delirium. All 3 reviews concluded that among the numerous scales of nonverbal behavioral pain indicators in use, none are more reliable or valid than others, and none are convincingly appropriate for use in this population. The reviews included a total of 13 scales, and the PACSLAC and PAINAD appear to have the best psychometric properties. The value of these measures in decision-making is unclear, however, because cutoff values for these scales have not been established. We found no studies that directly linked differences in assessment and management with clinical outcomes or safety in this subgroup of patients.
4a | For inpatients with dependencies on tobacco, alcohol, stimulant, marijuana, or opioids, how do differences in assessment and management of acute pain affect clinical outcomes or safety? | Case reports, retrospective studies, and expert opinions identified by a systematic search | Low | Guidelines for managing acute pain in opioid-tolerant patients and patients with substance abuse disorder are based on case reports, retrospective studies, and expert opinion were compiled in a good-quality systematic review. The evidence on which these recommendations are based is weak, however, being derived from case reports, retrospective studies and expert opinion
4b | How do the assessment and management of acute pain differ between patients on pre- existing opioid therapy and patients with opiate addiction? | None | Very Low | Definitions for tolerance, physical dependence, and addiction, and pseudoaddiction are not universally agreed upon, and estimates of the prevalence of addiction in patients with chronic pain varied widely, from 0.2% to 50%. We found no studies of whether in acute care settings, clinicians can distinguish addiction from physical dependence or pseudoaddiction. We also found no studies of the discriminant ability of individual signs and symptoms of addiction to identify distinct groups of patients for whom different assessment and treatment strategies are most effective. Guidelines for managing post- operative pain specify that initial dosing should be adjusted for patients who take opioids for chronic nonmalignant pain, and while these guidelines for initial dosing have been generalized to patients who have acute pain from other causes, we did not find any evidence about effectiveness or safety in the target population.

## Recommendations for future research

Pain is a prevalent problem for medical inpatients, and research has not addressed this setting effectively. The lack of evidence suggests that the VA should characterize current practice, avoid overly prescriptive standards, and emphasize a robust research agenda. Given that pain intensity is used widely, and that outpatient research raises some questions about the accuracy and relevance of single item screening for pain to improved patient outcomes, veterans might benefit from clinical research that:

1. Tests use of pain intensity along with other approaches (automated nurse/physician alerts, expanded screening items/paradigms, patient direct-triggered nurse/physician alerts) to better link screening to intervention. Psychometric evaluation is needed as one aspect of this research.
2. Draws upon quality improvement research to evaluate the efficacy of key intervention components.
3. Evaluates different initial treatment intensities including the clinical effectiveness and safety of PCA, but not excluding high intensity oral regimes (which are used in lieu of PCA in places such as Australia). These studies should stress the evaluation of alternative follow-up strategies and ascertain the risk/benefit and ceiling effects of alternative approaches to medical pain management.
4. Specifically addresses basic clinical science of pain in delirium, severe mental illness (such as schizophrenia which you highlight) and dementia (such as identifying a ‘gold standard’ for validity – e.g., fMRI vs. observation), and clinical studies that address 1–3 should not exclude veterans with substance abuse disorder. Furthermore, studies that examine treatment in those populations and that include outcomes relevant to prior abuse such as triggering of recurrent abuse, dysphoria, etc., are needed.
5. Evaluates performance measures that go beyond assessment to include prompt treatment and successful alleviation of pain in the medical inpatient setting (see Table 6).

Table 6 Examples of indicators for measuring aspects of pain management

Performance measure | Developed for population/setting | Numerator | Denominator
Assessment and diagnosis
Percentage of patients with documented assessment for pain using standardized tool on admission108 | Long-term care setting | Number with documented admission assessment for pain using standardized tool | All patients
Percentage of patients with documented care plan for acute or chronic pain108 | Long-term care setting | Number with documented care plan for acute or chronic pain | All patients with reported pain
Percentage of patients receiving physical exam to assess for causes of pain108 | Long-term care setting | Number receiving physical exam to assess for causes of pain | All patients with reported pain
Percentage with cognitive and language problems receiving targeted pain assessment108 | Long-term care setting | Number with cognitive and language problems receiving targeted pain assessment | Patients with diagnosed cognitive and/or language deficit
Percentage with periodic documented assessment by nursing staff of effectiveness of pain management108 | Long-term care setting | Number with periodic documented assessment by nursing staff of effectiveness of pain management | Patients with reported pain
Percentage with periodic documented assessment of effectiveness of pain management by medical doctor (MD)108 | Long-term care setting | Number with periodic documented assessment of effectiveness of pain management by medical doctor (MD) | Patients with reported pain
Percentage with documented complete assessment of pain covering all pertinent components of pain108 | Long-term care setting | Number with documented complete assessment of pain covering all pertinent components of pain | All patients with reported pain
Screening for pain109 | Vulnerable elders (aged 65+) | Number of patients screened for chronic pain in initial evaluation | All vulnerable elders
Screening for depression109 | Vulnerable elders (aged 65+) | Number of patients screened for depression | Vulnerable elders with presenting with chronic pain
Treatment/management
Percentage with documented absence of pain symptoms after treatment108 | Long-term care setting | Number with documented absence of pain symptoms after treatment | All patients with reported pain who received treatment
Percentage with documented reduction of pain symptoms108 | Long-term care setting | Number of patients with documented reduction of pain symptoms | All patients with reported pains
Percentage of patients with orders for not recommended drugs108 | Long-term care setting | Number of patients with orders for not recommended drugs | All patients receiving medications to treat pain
Percentage of patients with appropriate treatment for pain108 | Long-term care setting | Number of patients with appropriate treatment for pain | All patients with reported pain
Percentage of patients prescribed narcotics for pain with appropriate bowel management program in place108 | Long-term care setting | Number of patients prescribed narcotics with appropriate bowel management in place | All patients receiving narcotics to treat pain
Percentage with adverse drug reactions (ADRs) to pain medications108 | Long-term care setting | Number of patients with adverse drug reactions (ADRs) related to pain medications | All patients receiving pain medication
Percentage with controlled adverse drug reactions (ADRs) to pain medications108 | Long-term care setting | Number with controlled adverse drug reactions (ADRs) to pain medications | All patients with reported pain receiving pain medication who had an adverse drug reaction (ADR)
Addressing risks of NSAIDs109 | Vulnerable elders (aged 65+) | Number of patients whose medical record indicates whether s/he has a history of peptic ulcer disease, and if a history is present, documentation of justification of NSAID use | All vulnerable elders who have been prescribed a cyclooxygenase nonselective NSAID for the treatment of chronic pain
Constipation with opioid use109 | Vulnerable elders (aged 65+) | Number of vulnerable elders offered a bowel regimen, or whose medical record documents the potential for constipation or explains why bowel treatment is not needed. | All vulnerable elders treated with opioids for chronic pain
Meperidine not used109 | Vulnerable elders (aged 65+) | Number of patients requiring analgesia who were not given meperidine | All vulnerable elders who require analgesia
Percentage who reported how often their pain was controlled110 | Adult inpatients | The number of respondents from the denominator who indicated “Always,” “Usually”, “Sometimes,” or “Never” on the two questions regarding their experiences with control of their pain | Hospital inpatients with an admission during the reporting period who answered the “Pain Management” questions on the CAHPS Hospital Survey

Additional recommendations pertinent to VA care can be found in Buffum et al.97