# Evidence Summary Tables

Summary Table 1 Studies on methods of pain assessment (KQ1)

Author, Year | Study Design, setting | Sample size | Clinical condition/ baseline pain | Intervention/exposure of interest | Outcomes measured | Results
Carey, 1997^1^ | Prospective cohort | 267 | 39.5% acute pain, 40.3% chronic pain. 20.9% reported no pain on admission. Mean for pain intensity ranged from 5.09–5.75. | Patients rated the intensity of pain using each of the 3 scales once over the next 24 hours were also asked which of the scales was easiest to use, whether the scale was helpful or needed further explanation, and employment and education data. | Use of 3 self-rated pain scales; questionnaire also collected demographic information and perceptions about scales. | Patients most frequently selected the VAS faces scale (48.6%), followed by the number scale (35.3%) and line scale (16.1%). None of the demographic variables were associated with preference. Reliability coefficient between scales (Chronbach’s alpha) was 0.88. Most (85.8%) patients indicated that a pain rating scale helped them to describe their pain to the nursing staff.
Luger, 2003^2^ | Single-site prospective study, convenience sample in Innsbruck, Austria | 10 EMS technicians, 10 EMS drivers, 2 ER physicians; 15 trauma patients and 36 nontrauma patients (mostly cardiovascular disease). | 15 trauma patients: 7 fractures or lacerations, 5 blunt injuries, 3 penetrating wounds. | Pain assessment was performed at the beginning of emergency care before analgesics, during transport, and upon arrival at the hospital immediately prior to hospitalization. | Severity of pain assessed by patient; EMS physician; EMS technician; EMS driver; at 3 time points (on the scene, during transport, and on arrival at hospital) | The EMS physician underestimate pain 47% of the time; the EMS technician underestimated pain 53% of the time; the EMS driver underestimated pain 57% of the time. The disparity was greatest (60–68%) among patients with severe pain, and lowest (28–36%) among patients with mild pain. The pain intensities on the VAS and VPS were highly correlated (r2=0.86, p=0.0001).
Nelson, 2004^3^ | Retrospective cohort study at a suburban university-based ED | 521 before the mandatory pain scale; 479 after introducing the pain scale to the ED, | Renal colic, extremity trauma, headache, opthalmologic trauma, or soft tissue injury. Pain varied from 0–10. 8% of patients who reported 0 received analgesia, compared with 74% who reported 9, and 69% who reported 10 as baseline pain. | The standard triage form was revised to include a pain scale in the vital signs section, and the pain assessment was made at triage at the same time as presentation vital signs were assessed. ED staff and patients were not made aware of the study or alerted to the intervention. | 1) The proportion of patients who received oral or parenteral analgesia for their pain while in the ED; 2) the time to analgesia administration | The proportion of patients who received analgesia after introduction of the pain scale increased from 25% to 35% (p<0.001). The mean time from triage to analgesia administration was 152 minutes before the intervention, and 113 minutes after (mean difference 39 minutes, 95%CI −7 to 84) but the difference was not statistically significant. Patients with diagnostic uncertainty who received further evaluation were less likely to receive analgesia. 34% who received no workup received analgesia, while only 27% did who underwent a workup (p=0.022). In patients with headache, 23% who underwent CT were treated for pain, whereas 62% of those who did not undergo CT were treated (p<0.001)
Morrison, 2006^4^ | Controlled clinical trial in an 1171-bed hospital in Mt. Sinai Hospital, New York. | 3964 adults | 9 medical/surgical units were selected for inclusion based on similar baseline patient demographics and pain scores (3 general medicine, 2 general surgery, 2 specialty surgery, 1 oncology, and 1 mixed oncology/general medicine). 32–38% surgical pts10–16% cancer pts1.5 – 4.8% AIDS pts56% had moderate to complete relief from pain medication29–32% had moderate to severe pain at study enrollment | Education in pain management (months 0–4) was followed by a series of additive 6 to 7-month intervention periods: 1) patient education and nursing pain assessment of current and worst pain, pain relief, and pain acceptability; 2) audit and feedback to nursing staff of patients’ pain intensity and staff compliance; and 3) a computerized clinical decision support system (CDSS) to guide analgesic prescribing. | Patients were interviewed within 48 hrs of admission and then once daily. Patients were asked to rate current pain, worst pain over 24 hrs, their pain relief with analgesics, and whether their pain was acceptable to them. Pain and pain relief were rated on 4-pt scales. Outcomes included measures of pain assessment, pain severity, and analgesic prescribing. % of patients who had a daily pain assessment for each shift; % of pts wioth moderate to severe pain 72–96 hrs later, mean pain scores for the first 72 hrs or on postop days 1–3 | Pain documentation was improved by >80% using an enhanced pain assessment instrument combined with either audit and feedback or a computerized decision support system. The enhanced pain scale was associated with increased analgesic prescribing. Patients on units using the enhanced pain scale were significantly more likely to have their pain assessed than those on units in which the 1-item pain scale was used (p<0.001). Audit and feedback of pain results was associated with significant increases in pain assessment rates compared with units without audit and feedback (p<0.001). Adding the CSS was associated with significant increases in pain assessment only when compared with units that lacked audit and feedback (p<0.001).Overall the % of pts who received at least 1 pain assessment per day increased from 32.1% with the standard pain assessment to 79.3% when the enhanced pain scale was combined with the CSS, and to more than 80% for interventions using audit and feedback.

Summary Table 2 Studies on the timing and frequency of pain assessment, and timing of treatment (KQ1)

Author, Year | Study Design, setting | Sample size | Clinical condition/ baseline pain | Intervention/exposure of interest | Outcomes measured | Results
Arendts, 2006^5^ | Retrospective cohort study in an Australian ED | 857 | Thoracic, including cardiac 12.9%, abdominal 30.6%, urological 11.4%, gynecological 4%, trauma 31%, neurological 35%, and misc. 6.6%. 15% were admitted to critical care, 49% admitted to general ward, and 19% admitted to ED observation | Morphine was the drug used in 94% of cases. | Time from arrival to first dose of opiate. Patients were grouped in 2: time <60 minutes, and time >=60 minutes. | Median time to first dose of opiate = 53 min. 73.5% received no alternative analgesia prior to opiate. Patients with 60+ minute delay were more likely to be female, older, of lower triage acuity, seen by junior medical staff, suffering from nontrauma-related illness, and admitted to hospital rather than discharged. These predictors were significant in multivariate analysis.
Grant, 2006^6^ | Retrospective review of patient records | 473 | 0r 473 pain patients, 213 (45%) had severe pain and 105 (22%) had moderate pain. By type of pain: Chest pain: 14–17% Abdominal pain: 19–21% Headache/neuropathi c: 8–11% Muscular: 29–32% Skeletal: 11–15% Ears, nose throat: 2–3% NOS 6–12% | Any form of analgesia | Time intervals between patient arrival, assessment, and delivery of analgesia. | For patients with moderate pain v. severe pain, mean time interval (min):Arrival to doctor assessment: 142 v 42 Arrival to prescription of analg: 168 v 58 Arrvial and receipt of analg: 236 v 72 Delay btw prescription and administration of analgesia: 68 v 14.% of patients who received analgesia within time frame meeting BAEM guidelines: 24% in severe pain, 18% in moderate pain. 32% of patients were re-evaluated in terms of analgesia requirements.
Hwang, 2006^7^ | Retrospective review of medical records from a prospective cohort study | 158 | Patients reporting complaint of pain: 81% | Transfer administrative data (ADT) on time of registration and discharge was used to determine ED crowding risk factors: ED census and mean ED length of stay (LOS) during the hour the index hip fracture patient arrived. | 4 quality measures: 1) time to pain assessment by a physician; 2) documentation of administration of pain medication 3) type of analgesic (opioid v nonopioid (NSAID, acetaminophen) if given; 4) time to pain treatment | Minutes to first documented pain assessment, mean (range): 40 (0–600)Minutes to first documented pain treatment: 141 (10–525)Delay in treatment, minutes: 122 (0–526)64.1% received analgesia for pain (57% opioids, 7% nonopioids).32.8% of patients for whom opioid was prescribed received meperidine. ED crowding at census levels greater than 120% bed capacity was significantly associated with a lower likelihood of documentation of pain assessment and longer times to pain assessment, in a multivariate analysis that adjusted for age, gender, RAND score, dementia, and mean ED LOS >100% annual.
Ranji, 2006^8^ | Systematic Review of RCTs of opiate analgesia v placebo in acute abdomen | 9 studies in 1062 adults, and 3 studies in 291 children. | 3 studies enrolled only patients with right lower quadrant pain; all others enrolled patients with undifferentiated acute abdominal pain. | use of opiate analgesia in acute abdomen | Effect of opiates on patient history (potential to minimize previously concerning symptoms v. increasing its accuracy by calming the patient); on the physical examination; and on potential management errors | 11 comparisons from 9 studies in adults showed a trend toward changes in the physical examination with opiate administration, with a summary RR of 1.51 (95%CI 0.85 – 2.69). There was significant heterogeneity among the studies; in 3 comparisons, pain relief reported by the opiate group did not significantly differ from placebo. Studies did not generally distinguish between potentially beneficial changes such as improved localization of tenderness and potentially harmful changes such as changes in peritoneal signs. In 2 studies, loss of periotneal signs after analgesia occurred in 5.6% to 18.7% of patients with opiates, compared with 2.6% to 7.7% of those in the control group. Diagnostic accuracy: a meta-analysis of 4 adult studies indicated no significant change in the rate of incorrect management decisions with opiates vs. placebo. Analgesia was adequate in all these studies, and no significant heterogeneity was found. The frequency of possible unnecessary surgeries was similar between opiate and control groups (7.6% v 7.9%). Meta-analysis showed a non-significant trend toward fewer unnecessary surgeries among patients with opiates.
Shabbir, 2004^9^ | Prospective study in a direct access A&E department where patients were immediately assessed by the surgical on-call service. | 100 | Acute abdominal pain. Clinical diagnoses included non-specific abdominal pain, PID, peptic ulcer disease, pancreatitis, appendicitis, renal, cholecystitis. | Most common drugs used: diclofenac 37% pethidine 26% Most common routes used: 80% intramuscular route 0% received intravenous analgesia. | Waiting time for analgesia and its relationship to subjective visual analogue pain scores and clinical diagnoses | Mean waiting time for analgesia was 1.4 hours (range 2 min to 14 hr).Female patients had a longer mean wait time than males (129 min v. 69 min, p=0.09). Patients admittted at nighttime received analgesia quicker (mean 76 min) than during the day time (mean 114 min). 77% were satisfied with the adequacy of analgesia once given; 23% thought the pain relief was not sufficient. Neither clinical diagnosis nor age influenced the timing of analgesia.
Vila, 2005^10^ | Retrospective chart review, single hospital: H.Lee Moffitt Cancer Center and Research Institute | Pre-intervention: 79 opioid ADRs for 117,672 inpatient hospital days, Post-intervention: 67 opioid ADRs for 65,388 inpatient hospital days | Cancer patients | All nursing staff and support personnel were required beginning January 2001 to document each patient’s rating of their pain intensity using a numerical scale, along with other vital signs with every routine patient assessment. | Change in patient satisfaction and opioid-related ADRs, including oversedation or respiratory depression requiring discontinuation of theopioid or reversal with naloxone, in the 4 years before and 2 years after implementation of new pain management standards. | Pre-intervention: 79 opioid ADRs for 117,672 inpatient hospital days, of these 13 involved oversedation. Post-intervention: 67 opioid ADRs for 65,388 inpatient hospital days; of these there were 16 oversedation events. There was a significant increase in the incidence of both events (opioid ADRs and cases of oversedation) post-NPTA (p=0.01 and p=0.03 respectively). The overall rate of ADRs increased by 49%, with a rate ratio of 1.49 (95%CI 1.08–2.07)67% of patients received analgesia within 1 hour after presentation; approximately 25% waited over 2 hrs. Patient satisfaction ratings increased significantly before and after the NPTA period. (p<0.00001)

Summary Table 3 Studies on the effectiveness and safety of patient-controlled analgesia for acute pain (KQ2)

Author, Year | Study Design, setting | Sample size | Clinical condition/ baseline pain | Intervention/exposure of interest | Results
Evans, 2005^11^ | RCT, not placebo-controlled, in an ED | 86; 43 in each group | Trauma patients, mostly fracture: 53.4% control, 74% PCA | After baseline measures of VAS, BP, pulse, GCS, SaO2, respiratory rate, an IV cannula was inserted. Controls were given 0–10 mg morphine by IV, titrated by a nurse. Morphine was given at a rate of 1–2 mg/min until by patient’s responses pt was comfortable. Pts were then asked to call for further analgesia if needed, and nurse was expected to check pt periodically per ED guidelines. PCA group pts were instructed in the use of the PCA, which administered a 5 mg loading dose with a subsequent bolus dose of 1mg and a lockout interval of 5 minutes. Pain scores and physiological measurements were made at 0, 5, 15, 30, 45, 60, 90, and 120 minutes. Patients were also given 50 mg of cyclizine to minimize nausea and vomiting. Recording of AEs were made by observation. At least 12 hrs after admission to a ward or discharge, patients were contacted by the researcher to complete a satisfaction questionnaire. | The mean pain scores for PCA and controls were similar (4.8 and 4.8, p=0.578). Area under the curve analysis of VAS pain scores confirmed that there was no significant difference between the 2 groups (p=0.784) Twice as much morphine was given to the PCA group, despite the similarity in VAS scores: mean mg PCA v. control: 18.83 v. 7.65. Mean morphine amt delivered over mean time: 7.26 mg/h PCA, 4.03 mg/h control. AEs: PCA patients experienced more events (p ns), most commonly mild sedation. There were no significant differences in the satisfaction questionnaires between the 2 groups.
Fulda, 2005^12^ | DB RCT, placebo-controlled | 44; 22 in each group | All had thoracic fractures: Unilateral rib fractures = 59% Bilateral rib fractures: 27% The mean injury severity score was 10.5 in the NMS group, 9.8 in the PCA group. | Randomized to 2 groups: nebulized morphine (NMS) or control group (PCA morphine). The PCA group received nebulized saline every 4 hrs with PCA morphine; the NMS group received nebulized morphine every 4 hrs with PCA saline. Pain was considered controlled if VAS <=4 and patient stated pain was well controlled. Patients with uncontrolled pain after 30 minutes Patients in NMS group received additional PRN doses of nebulized morphine every 30 minutes up to 2 treatments, and had the PCA pump adjusted to provide PCA doses of saline every 15 min. Patients in PCA group had PCA delivery adjusted to include addition of 1 mg of morphine every 15 minutes on demand, and received 2 additional PRN nebulized saline treatments every 30 minutes up to 2 treatments | The NMS group required more morphine than the PCA group: the average 4-hr morphine dose was 11.96 for the NMS group, and 6.22 for the PCA group (p<0.001). Although most (74.3%) of observations, patients were alert without evidence of increased sedation, those in the NMS group had lower sedation scores than the PCA group (0.33 v. 0.56, p=0.03). Only 1 patient in the NMS group exceeded sedation level of 1, whereas 5 in the PCA group exceeded this level. However, these 6 patients had less morphine on average than the group as a whole, so there was no correlation. Patients with NMS had a significantly lower mean heart rate, and a non-significantly higher respiratory rate compared with the PCA group. Effect on pain level was similar between NMS and PCA morphine Mean pain score for each group, baseline v. pretreatment v. posttreatment: NMS: 5.38 v. 3.52 v. 2.59, mean overall = 3.38 PCA: 5.73 v. 3.89 v. 2.64, mean overall = 3.84
Moon, 1999^13^ | Controlled CT at Univ Cincinnati | 34 enrolled; 10 excluded from analysis | Significant thoracic traumatic injury | Epidural analgesia vs. PCA Patients randomized to PCA received a loading dose of IV morphine 0.1 mg/kg before establishment of PCA. The infusion was titrated by a member of the acute pain service to maximize pain relief before handing over the control of the system to the patient. The PCA regimen used morphine 1 mg/ml in bolus doses of 2 mg with a lockout duration of 10 minutes. There was no background infusion. Thoracic epidural catheters were placed by an anesthesiologist in the epidural space between T5 and T7. A 3-ml test dose of lidocaine 1.5% with epinephrine 1:200,000 was then administered through the epidural catheter to exclude subarachnoid or intravascular location of the catheter. Sensory testing of appropriate thoracic dermatomes was performed 10 mintues after to confirm epidural placement of the catheter. The catheter was further dosed with an injection of fentanyl (50 ug) and 3 mg preservative-free morphine. Within 1 hr of placement, a continuous infusion of bupivacaine 0.25% and morphine 0.005% was initiated at a rate of 4–6 ml/hr using an infusion pump. A member of the APS adjusted the infusion rates to opitmize pain relief and minimize side effects. | During the first 24 hrs of study, the epidural group had a significant reduction in pain score with coughing, compared with PCA patients. After 48 hrs there was no difference in pain scores btw the 2 routes of opioid administration. On day 3, the epidural group had a 38.7% reduction in pain score compared with the PCA group, whose score was approximately 6.2, the same as for day 2. The epidural group’s pain score on day 3 (3.8) was significantly lower than that of the PCA group (p<0.05). PCA patients had a gradual 15% decline in MIF during the study period, whereas the epidural group had a continual increase (23%) By day 3 the epidural group had a significant increase in MIF v. PCA. Tidal volume continually fell for the PCA group (56% on day 3 compared with day 1), but the epidural group had a continual improvement (45% increase from day 1)
Wu, 1999^14^ | Retrospective cohort study | 64, 32 in each group | Multiple (3+) rib fracture from motor vehicle crash N fractured ribs: 5.6 epidural vs 4.4 PCA (p=0.01) Injury severity score: 21.6 epidural vs 21.9 PCA (p=ns) | Patients who received IV PCA were able to obtain 1 mg of morphine every 6 minutes through the PCA pushbutton. The morphine could be increased by physician order. Epidural catheters were inserted in the thoracic region (T5–T9) with local analgesia (0.125 to 0.25% bupivacaine) and fentanyl (2.5 ug/mL), and the initial infusion rate was 5 to 8ml/h as adjusted by the Acute Pain Service. | There was no difference between PCA and epidural analgesia in duration of analgesia, length of ICU stay, or length of hospital stay. Patients with epidural analgesia had significantly lower pain ratings at all time intervals, with the exception of baseline scores (difference of 0.5 to 1 point higher in the PCA group, p-value ranging from 0.005 to p<0.001 at various time points). There were no differences between the groups with respect to pulmonary, cardiac, or neurologic complications.

Summary Table 4 Studies on the management of acute pain in renal colic and biliary stone (KQ2)

Author, Year | Study Design, setting | Sample size | Clinical condition/ baseline pain | Intervention/ exposure of interest | Outcomes measured | Results
Holdgate, 2007^15^ | Cochrane systematic review, NSAIDs | 20 trials with 1613 | Most studies included only participants with renal calculi confirmed on subsequent testing, and excluded patients with negative results on followup tests. | Trials compared one of 5 NSAIDS (diclofenac, indomethacin, indoprofen, ketorolac, tenoxicam), to 1 of 7 opioids (pethidine was used in 10 of the 20 trials). The intramuscular route was most commonly used for each drug type (10 trials), followed by the intravenous route (7 trials). | Patient-rated pain and/or time, time to pain relief, need for rescue medication, rate of pain recurrence, adverse events. Major events were defined as GI hemorrhage, renal failure, hypotension, and respiratory depression. Minor adverse events were defined as GI disturbance without bleeding, dizziness, sleepiness. | Patients receiving NSAIDs reported lower pain scores than patients receiving opioids in 10 of 13 studies, though the differences were small. No pooled results on efficacy due to heterogeneity. Use of rescue analgesia was significantly less likely with NSAIDs (RR 0.75, 95%CI 0.61–0.93). More AEs with NSAIDs in the majority of trials, especially vomiting with pethidine. The reviewers concluded that both NSAIDs and opioids provide effective analgesia in acute renal colic, but opioids, particularly pethidine, result in a higher incidence of vomiting and other adverse events.
Jasani, 1994^16^ | Prospective DB RCT comparing hydrmorpho ne v. meperidine in a tertiary care center with 93,000 annual ED visits. | 36 hydrom orphone, 37 meperidine. | Presumed ureteral colic | Comparable doses of the 2 medications were administered at t=0. The patients were randomized to receive either 50 mg meperidine (M) or 1 mg hydromorphone (H) IV in a double-blind manner. | Remedication interval for patients requiring additional analgesia; proportions of men and nonresponders | Baseline VAS pain scores were similar between treatment groups at t=0. The H group had significantly lower pain intensity levels at each timepoint. The M group had significantly more nonresponders than the H group. Significantly fewer patients required IV pyelograms in the H group (28% v 54%, p=0.05) and there were fewer admissions in the H group than the M group (25% v 49%, p=0.08). AEs: there were more patients with nausea and vomiting in the M group compared with H: 40% v 28%, p=0.31. More patients on H had dizziness than did M (22% v 11%, p=0.25. The two groups experienced similar rates of drowsiness (41% H v 46% M).
Muriel-Villoria, 1995^17^ | IM v. IV dipyrone | Varied by intervention, 22–70 | Renal colic | dipyrone 1g IM + placebo IV dipyrone 1g IV + placebo IM dipyrone 2g + placebo IM dipyrone 2g + placebo IV diclofenac 75mg IV + placebo IM | Proportion of patients with >50% improvement | Significant differences: dipyrone 2g IV > 1g IV at 10’ dicloefenac 75 mg IV > IM at 20’ dipyrone 1g IV > 1g IM at 20’
Nelson, 1988^18^ | Rectal v. IV indomethacin | Varied by intervention, 53–63 | Renal colic | indomethacin 100mg PR indomethacin 50mg IV | VASPI at 10’ | IV significantly lower than PR; at 30’ no difference. Supplementary analgesics: pr 16/47; IV 8/37
Nissen, 1990^19^ | Rectal v. IV indomethacin | Varied by intervention, 44–54 | Renal colic | indomethacin 100mg PR indomethacin 50mg IV | VASPI at 10’ and 20’: | VASPI: IV significantly lower than PR; at 30’ no difference. Use of supplementary analgesics: PR 17/63 v. IV 5/53 (p=0.03).
Uden, 1984^20^ | Single-blind, randomized trial Biliary stone: subcutaneous injection of dihydromporphinone v. IV indomethacin | 42 | Acute attacks of biliary stone pain | Group D received 1 mL of dihydromorphinone and patients in Group I received 50 mg of indomethacin intravenously. The surgeon on duty conducted patient exam and provided information about the ongoing study. (Subsequently?) the attendant nurse provided the drug injection, but the examiner was blinded to the treatment. Pain was evaluated at baseline and at 10 and 30 minutes after drug injection. In cases of insufficient pain relief, a second injection was given. | Pain (VAS) at 10 and 30 minutes after administering treatment | N/total free of pain at 10 minutes and 30 minutes: Group D: 2/21 at 10 min, 11/21 at 30 min Group I: 2/21 at 10 min, 10/21 at 30 min Mean scores at baseline, 10 minutes, and 30 minutes: Group D: 71.8, 44.1, 14.2 Group I: 68.5, 32.4, 15.8 Pain reduction within each group was statistically significant (p<0.01) whereas the difference between the two groups was not. AEs: 2 pts in each group felt nausea and vertigo. 1 in D developed a red, itching subcutaneous infiltration at injection site. 1 in Group I vomited during injection, another in Group I experienced nasal congestion.

Summary Table 5 Studies on the effectiveness and safety of neural blockade for acute pain (KQ2)

Author, Year | Study Design, setting | Sample size | Clinical category; baseline pain | Intervention/exposure of interest | Outcomes measured | Results
Chudinov, 1999^21^ | Randomized trial in orthopedic hospital, Israel | 40 | Hip fracture, undergoing surgery | Psoas compartment block using 2mg/kg/body weight of 0.25% bupivacaine with adrenaline (0.8 ml/kg) and supplementary doses as required via catheter vs. no block | Length of follow-up: perioperative period only (72 hours). Pain relief assessed by VAS. Adverse effects of the block | The psoas compartment block resulted in significantly less pain at 8 and 16 hours pre-operatively, and also at 16, 24, and 32 hours post-operatively. Proportionally more patients who received the psoas block were satisfied with pain control compared with controls.
Haddad, 1995^22^ | Randomised trial | 50 | Extracapsular hip fracture | Femoral nerve block inserted at time of admission using 0.3ml/kg of 0.25% buipivacaine vs. control group (no injection | Mean pain score using VAS: pre-block and at 15 mins, 2 hrs and 8 hrs. Amount of analgesic administration within first 24 hrs of co-codramol, voltarol, pethidine. Incidence of respiratory infections, CVA, pulmonary embolism, deep vein thrombosis, urinary tract infection, skin breakdown, mortality, failed nerve block. | Femoral nerve block provided a greater reduction in the mean pain scores that was statistically significant at 15 minutes (mean change −2.6 v. −0.7) and at 2 hours (mean reduction −3.0 v. −1.2). The number of parenteral analgesic drugs administered in the 24 hrs from admission was reduced for the nerve block group. Local or systemic complications did not occur with the use of femoral nerve blocks.
Scheinin, 2000^23^ | Randomized trial, orthopedic hospital in Finland | 59 | Hip fracture, undergoing surgery | Lumbar epidural using bupivacaine and fentanyl inserted within 6 hrs of admission. Infusion rate adjusted according to patients requirements vs intramuscular opiate (oxycodone 0.1–0.15mg/kg) at 6 hourly intervals as necessary. All patients operated on using spinal anesthesia | Length of follow-up for clinical outcomes was 3 days. Mortality for 3 years was determined using central statistic register. Pain relief as assessed by VAS (scale 0–100). Ischemic episodes as determined by continuous electrocardiogram recording; nocturnal oxygen saturation; itching; nausea; quality of sleep; mortality. | Pre-operative pain scores did not significantly differ (p=0.42) continuous epidural infusion of bupivacaine plus fentanyl (mean value 34) vs controls who received parenteral opiates IM (mean 42), although post-operative pain scores were significantly (p=0.006) reduced in the epidural group (mean 22) compared with intramuscular opiates (mean 35). No mention of complications specific to the treatment.
Halbert, 2002 #1428^24^ | SR of 12 controlled trials that reported phantom pain as an outcome | Included 12 trials, total 375 patients (both men and women), ages 47–75. | 8 trials of treatment of acute phantom pain with preoperative, intra-operative, and early (<2 weeks) postoperative interventions | 8 trials on phantom limb pain studied epidural treatments (3 trials); regional nerve blocks (3); calcitonin (1); and transcutaenous electrical nerve stimulation (1). 4 trials on late postoperative pain studied transcutaneous electrical nerve stimulation (2) and Farablock (a metal threaded sock) and ketamine (1 trial each). In 8 preop/intraop/early post-op trials, the interventions included epidural anesthesia (3 trials), regional nerve blocks (3), intravenous calcitonin (1) and TENS. Controls received a placebo consisting of a saline infusion or epidural anesthesia consisting of on-demand opioid analgesia. 5 trials used opioid analgesia, and 1 trial used sham TENS with and without chlorpromazine. Trials that used epidural anesthesia commenced 18–72 hours before surgery. Blockade anesthesia commenced during the operation or postoperatively. 4 trials of late postop interventions included TENS, Farabloc, vibratory stimulation, and infused ketamine. | Effect on phantom limb pain at various time points up to 12 months post-amputation | Up to 70% of patients have phantom limb pain after amputation. There is little evidence from randomized trials to guide clinicans with treatment. Evidence on preemptive epidurals, early regional nerve blocks, and mechanical vibratory stimulation provides inconsistent support for these treatments.
Knoop, 1994^25^ | Randomized prospective, nonblinded clinical study, convenience sample; inner-city and community hospital ER | 30 | Patients had 3rd or 4th finger injuries including and distal to the proximalinterp halangeal joint that required digital anesthesia. Injuries included lacerations (67%) and infections (27%). | Digital blocks and a metacarpal block were performed on each patient, in randomized order. Additional anesthesia was given and noted when required for all patients. After a period of no less than 10 minutes, the patient was treated in a mannger consistent with the injury (ie, sutures, incision, and drainage). | Patients immediately rated pain associated with each technique on a nonsegmented VAS. Efficacy was assessed by requirement for additional anesthesia and anesthesia to pinprick. Time to anesthesia was assessed after each block in 23 patients. Patients were asked which technique they thought was more painful or if there was no difference between the 2 techniques. Responses were recorded for 10 minutes. | Digital block was less painful than metacarpal block by both VAS and by verbal comparison, but the differences did not reach statistical significance. There were no sig. Diffs in the VAS scores of the first block compared with the second block. Mean VAS scores were 2.53 cm for digital block, and 3.35 cm for metacarpal block (p=ns). 40% of patients rated the digital block as more painful, and 7% noted no difference in pain between the blocks (p=ns). Digital block was found to be more efficacious as metacarpal block failed anesthesia to pinprick in seven of 30 metacarpol blocks (23%) compared with one of 30 (3%) for digital block (p=0.02). When requirement for additional anesthesia was assessed, digital block was adequate 97% of the time (29 of 30 blocks), while metacarpal block was adequate 87% of the time (26 of 30 blocks, p=ns). Time to anesthesia available in 23 patients was found to be significantly shorter for digital block compared with metacarpal block, with a mean of 2.82 minutes vs. 6.35 minutes (p<0.0001).

## References in Appendix E, Evidence Summary Tables

1 Carey SJ, Turpin C, Smith J, Whatley J, Haddox D. Improving pain management in an acute care setting. The Crawford Long Hospital of Emory University experience. Orthopaedic Nursing. Jul–Aug. 1997;16(4):29-36. [pmid: 9287814].
2 Luger TJ, Lederer W, Gassner M, Lockinger A, Ulmer H, Lorenz IH. Acute pain is underassessed in out-of-hospital emergencies. Academic Emergency Medicine. Jun. 2003;10(6):627-632. [pmid: 12782523].
3 Nelson BP, Cohen D, Lander O, Crawford N, Viccellio AW, Singer AJ. Mandated pain scales improve frequency of ED analgesic administration. American Journal of Emergency Medicine. Nov. 2004;22(7):582-585. [pmid: 15666265].
4 Morrison RS, Meier DE, Fischberg D, et al. Improving the management of pain in hospitalized adults. Archives of Internal Medicine. May 8. 2006;166(9):1033-1039. [pmid: 16682579].
5 Arendts G, Fry M. Factors associated with delay to opiate analgesia in emergency departments. Journal of Pain. Sep. 2006;7(9):682-686. [pmid: 16942954].
6 Grant PS. Analgesia delivery in the ED. American Journal of Emergency Medicine. Nov. 2006;24(7):806-809. [pmid: 17098101].
7 Hwang U, Richardson LD, Sonuyi TO, Morrison RS. The effect of emergency department crowding on the management of pain in older adults with hip fracture. Journal of the American Geriatrics Society. Feb. 2006;54(2):270-275. [pmid: 16460378].
8 Ranji SR, Goldman LE, Simel DL, Shojania KG. Do opiates affect the clinical evaluation of patients with acute abdominal pain?. JAMA. Oct 11. 2006;296(14):1764-1774. [pmid: 17032990].
9 Shabbir J, Ridgway PF, Lynch K, et al. Administration of analgesia for acute abdominal pain sufferers in the accident and emergency setting. European Journal of Emergency Medicine. Dec. 2004;11(6):309-312. [pmid: 15542986].
10 Vila H Jr, Smith RA, Augustyniak MJ, et al. The Efficacy and Safety of Pain Management Before and After Implementation of Hospital-Wide Pain Management Standards: Is Patient Safety Compromised by Treatment Based Solely on Numerical Pain Ratings?. Anesth. Analg. August 1, 2005. 2005;101(2):474-480. [pmid: 16037164].
11 Evans E, Turley N, Robinson N, Clancy M. Randomised controlled trial of patient controlled analgesia compared with nurse delivered analgesia in an emergency department. Emergency Medicine Journal. Jan. 2005;22(1):25-29. [pmid: 15611537].
12 Fulda GJ, Giberson F, Fagraeus L. A prospective randomized trial of nebulized morphine compared with patient-controlled analgesia morphine in the management of acute thoracic pain. Journal of Trauma-Injury Infection & Critical Care. Aug. 2005;59(2):383-388. discussion 389–390.
13 Moon MR, Luchette FA, Gibson SW, et al. Prospective, randomized comparison of epidural versus parenteral opioid analgesia in thoracic trauma. Annals of Surgery. May. 1999;229(5):684-691. discussion 691–682. [pmid: 10235527].
14 Wu CL, Jani ND, Perkins FM, Barquist E. Thoracic epidural analgesia versus intravenous patient-controlled analgesia for the treatment of rib fracture pain after motor vehicle crash. Journal of Trauma-Injury Infection & Critical Care. Sep. 1999;47(3):564-567.
15 Holdgate A, Pollock T. Nonsteroidal anti-inflammatory drugs (NSAIDS) versus opioids for acute renal colic [Systematic Review]. Cochrane Database of Systematic Reviews. 2007(2).
16 Jasani NB, O'Conner RE, Bouzoukis JK. Comparison of hydromorphone and meperidine for ureteral colic. Academic Emergency Medicine. Nov–Dec. 1994;1(6):539-543. [pmid: 7541310].
17 Muriel-Villoria C, Zungri-Telo E, Diaz-Curiel M, et al. Comparison of the onset and duration of the analgesic effect of dipyrone, 1 or 2 g, by the intramuscular or intravenous route, in acute renal colic. European Journal of Clinical Pharmacology. 1995;48(2):103-107. [pmid: 7589022].
18 Nelson CE, Nylander C, Olsson AM, Olsson R, Pettersson BA, Wallstrom I. Rectal v. intravenous administration of indomethacin in the treatment of renal colic. Acta Chirurgica Scandinavica. Apr. 1988;154(4):253-255. [pmid: 3287813].
19 Nissen I, Birke H, Olsen JB, et al. Treatment of ureteric colic. Intravenous versus rectal administration of indomethacin. British Journal of Urology. Jun. 1990;65(6):576-579. [pmid: 2196971].
20 Uden P, Starck CJ, Berger T. Comparison of indomethacin and dihydromorphinone in acute, biliary stone pain. Current Ther Res. 1984;36(6):1228-1234.
21 Chudinov A, Berkenstadt H, Salai M, Cahana A, Perel A. Continuous psoas compartment block for anesthesia and perioperative analgesia in patients with hip fractures. Regional Anesthesia & Pain Medicine. Nov–Dec. 1999;24(6):563-568. [pmid: 10588563].
22 Haddad FS, Williams RL. Femoral nerve block in extracapsular femoral neck fractures. Journal of Bone & Joint Surgery - British Volume. Nov. 1995;77(6):922-923. [pmid: 7593107].
23 Scheinin H, Virtanen T, Kentala E, et al. Epidural infusion of bupivacaine and fentanyl reduces perioperative myocardial ischaemia in elderly patients with hip fracture--a randomized controlled trial. Acta Anaesthesiologica Scandinavica. Oct. 2000;44(9):1061-1070. [pmid: 11028724].
24 Halbert J, Crotty M. Evidence for the optimal management of acute and chronic phantom pain: a systematic review. Clin J Pain. 2002;18(2):84-92. [pmid: 11882771].
25 Knoop K, Trott A, Syverud S. Comparison of digital versus metacarpal blocks for repair of finger injuries. Annals of Emergency Medicine. Jun. 1994;23(6):1296-1300. [pmid: 8198304].