# Inclusion/Exclusion Criteria

Code | Include /Exclude | Reason
I1 | Include | Published primary research, systematic review, or meta-analysis of studies that; a. Were conducted in inpatients with acute pain (including patients with impaired self-report; patients with prexisting opiate therapy; and patients with dependencies on tobacco, alcohol, opioids, or other substances); b. Report data on any of the following; i. Association between timing and frequency of pain assessment, severity of pain, and choice of treatment (e.g. regional blocks, medications, or other therapies); ii. Method of pain assessment (e.g. 11-point pain scale, visual analog scale, verbal descriptor scale; iii. Timing and route of administration of pain interventions (e.g. oral intermittent pharmacotherapy, intravenous therapy, psychological interventions, positioning, neural blockade, and patient-controlled analgesia); timeliness of enactment of treatment plans, changes in treatment plans; iv. Effect of coordination of care with the patient’s primary care physician or with a pain consultation service on choice of treatment, clinical outcomes, and safety; v. Patient outcomes, including degree of pain relief, pain intensity, emotional well-being, patient satisfaction, physical function, and fitness for rehabilitation of the underlying condition; vi. Safety outcomes; severity and frequency of side effects (including somnolence, respiratory depression, confusion, constipation, ileus, vomiting, non-allergic itching, weakness/numbness, and use of naloxone); vii. Length of stay; viii. Follow-up of pain
I3 | Include | Unpublished research meeting I1 criteria
I4 | Include | Non-systematic review or background article meeting I1 criteria
I5 | Include | Other (specify)
X1 | Exclude | Study outcome does not meet I1 criteria
X2 | Exclude | Study population does not meet criteria (e.g. outpatients; inpatients hospitalized 10 days or longer)
X3 | Exclude | Type of pain not within scope of review (e.g. post-operative pain, sickle cell disease, cancer pain, chronic pain in patients hospitalized 10 days or longer for whom pain is chronic or refractory)
X4 | Exclude | Pain intervention studied is not routinely available in the VA health system
X5 | Exclude | Non-English language, no abstract
X6 | Exclude | Non-human, animal
X7 | Exclude | Other (specify, e.g. off-topic)
X8 | Exclude | Wrong study design; no data