# Search Strategy and Table of Systematic Reviews

## Search Strategy

Database: Ovid MEDLINE(R) <1996 to April Week 1 2007>
Search Strategy:
1 | Analgesia/ or Analgesics, Opioid/ or Pain/ or Anti-Inflammatory Agents, Non-Steroidal/ or acute pain.mp. or Pain Measurement/ or Analgesics/ (89900)
2 | Meta-Analysis/ or “Review Literature”/ or systematic review.mp. (15321)
3 | 1 and 2 (661)
4 | limit 3 to english language (596)
5 | from 4 keep 1–596 (596)

Targeted search strategy for primary studies on KQ1:
Database: Ovid MEDLINE(R) <1950 to July Week 2 2007>
Search Strategy:
1 | exp Pain/ (212174)
2 | exp Pain Measurement/ (31393)
3 | ((assess$ or measur$) adj3 pain$).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (37632)
4 | acute pain$.mp. (2813)
5 | 1 or 2 or 3 or 4 (226036)
6 | exp Hospitalization/ (104116)
7 | exp Inpatients/ (6381)
8 | exp patient admission/ (12978)
9 | exp Emergency Medical Services/ (60608)
10 | 6 or 7 or 8 or 9 (163418)
11 | 5 and 10 (5687)
12 | exp Time/ (845509)
13 | 11 and 12 (778)
14 | limit 13 to (humans and english language) (657)
15 | from 14 keep 1–657 (657)

Targeted search strategy for primary studies on the use of PCA in non-surgical settings, for KQ2:
Database: Ovid MEDLINE(R) <1950 to July Week 3 2007>
Search Strategy:
1 | Analgesia, Patient-Controlled/ (2508)
2 | limit 1 to english language (2205)
3 | limit 2 to meta analysis (14)
4 | exp Surgical Procedures, Operative/ (1661433)
5 | su.fs. (1152982)
6 | exp Postoperative Complications/ (307984)
7 | 4 or 5 or 6 (2196325)
8 | 2 not 7 (612)
9 | from 8 keep 1–612 (612)

Initial exploratory search strategies for systematic reviews, conducted in January 2007 (postoperative pain was subsequently excluded from the scope):

Acute Pain Management: Postoperative and Inpatient Settings January 23, 2007

Search strategy 1: PubMed Clinical Queries - Limits; human, English

(pain [mh] AND (drug therapy [sh] OR therapy [sh] OR psychology [sh] OR surgery [sh])) AND systematic[sb]:

((pain, postoperative [mh] OR acute disease [mh]) AND pain measurement [mh]) AND systematic[sb]))

Search strategy 2: PubMed

pain, postoperative [mh] AND evidence-based medicine [mh] AND acute [tw] = 17

Search strategy 3: Cochrane library

Pain management

Pain (and) evidence (and) assessment

Pain in Record Title and management in Record Title and evidence in Record Title in Database of Abstracts of Reviews of Effects

(1-23-07)

Search strategy 4: PubMed : Acute pain in patients with cognitive impairment or acute psychiatric illness

pain [mh] AND (drug therapy [sh] OR therapy [sh] OR psychology [sh]) AND mental disorders [mh]

Search Strategy 5 - PM Clinical Queries –

pain [mh] AND (drug therapy [sh] OR therapy [sh] OR psychology [sh]) AND mental disorders [mh]

Search strategy 6: PM Clin Quer

(Pain [mh] AND (delirium [tw] OR dementia [tw])) AND systematic[sb]

(1-29-07 – Pubmed)

pain, postoperative [mh] AND (timing [tw] OR assessment [tw]) AND evidence based medicine [mh] = 19

pain measurement [mh] AND evidence based medicine [mh] = 104

March 20, 2007

Ovid search 1

1.pain, postoperative.mp. or Pain, Postoperative/

OR acute disease.mp. or Acute Disease/

AND

patient satisfaction.mp. or Patient Satisfaction/ = 298

Ovid search 2

pain measurement.mp. [mp=title, original title, abstract, name of substance word, subject heading word]

OR

acute disease.mp. [mp=title, original title, abstract, name of substance word, subject heading word]

AND

“Outcome Assessment (Health Care)”/

Ovid search 3 =6

pain, postoperative.mp. or Pain, Postoperative/

AND

patient satisfaction.mp. or Patient Satisfaction/

AND

questionnaires.mp. or Questionnaires/

## Cited systematic reviews and studies

Table of systematic reviews and studies cited, by key question

Title | Conditions | Special populations | KQ1 | KQ2 | KQ3 | KQ4
Acute Pain Management: Scientific Evidence.(1) | Post-operative pain and acute pain in spinal cord injury, burns, cancer, acute zoster, neurological diseases, haematological disorders (e.g. sickle cell disease) HIV/AIDS, renal and biliary colic, musculoskeletal and orofacial pain and headache, phantom limb pain | Elderly, opioid-tolerant patients, patients with obstructive sleep apnea, renal or hepatic impairment or a substance abuse disorder | (2, 3) | (4–18) | (19, 20) | (21–28)
Tools for assessment of pain in nonverbal older adults with dementia: a state-of-the-science review (29) | Types of pain not specified. The assessment scales measured pain by observation of behavioral indicators. | Nonverbal elderly patients with cognitive impairment | -- | -- | (30–39) | --
Observation scales for pain assessment in older adults with cognitive impairments or communication difficulties (40) | Types of pain not specified. The assessment scales measured pain by observation of behavioral indicators. | Elderly patients with cognitive impairments, communication difficulties, or both. | -- | -- | (30, 31, 33–35, 37–39, 41–45) | --
Pain in elderly people with severe dementia: a systematic review of behavioural pain assessment tools (46) | Types of pain not specified. The assessment scales measured pain by patient self-report, or behavioral measures. | Elderly patients with cognitive impairment | -- | -- | (30–33, 37, 38, 47–52) | --
Institutional Approaches to Pain Assessment and Management (2003).(53) | Postoperative pain, non-surgical pain, cancer, HIV disease, sickle cell crisis | -- | -- | (54–62) | -- | --
Do opiates affect the clinical evaluation of patients with acute abdominal pain? (63) | Acute abdomen | -- | -- | (64–72) | -- | --
Nonsteroidal anti-inflammatory drugs (NSAIDS) versus opioids for acute renal colic (73) | Acute renal colic pain | -- | -- | (74–92) | -- | --
Comparing analgesic efficacy of non-steroidal anti-inflammatory drugs given by different routes in acute and chronic pain: a qualitative systematic review (93) | Included 3 trials in renal colic | -- | -- | (94–96) | -- | --
Hydromorphone for acute and chronic pain (97) | Included one trial in patients with renal colic, and one trial in patients with biliary stone pain. | -- | -- | (98, 99) | -- | --
Pain management in hospitalized cancer patients: a systematic review (100) | Cancer | -- | -- | (101–105) | -- | --
Evidence for the optimal management of acute and chronic phantom pain: a systematic review. (5) | Phantom limb pain after amputation | -- | -- | (11, 12, 18, 106–114) | -- | --

### References in Appendix A, Table of Systematic Reviews

1 Australian and New Zealand College of Anaesthetists and Faculty of Pain Medicine. Acute Pain Management: Scientific Evidence. 2nd edition. Melbourne. Australian and New Zealand College of Anaesthetists. 2005.
2 Banos JE, Bosch F, Canellas M, Bassols A, Ortega F, Bigorra J. Acceptability of visual analogue scales in the clinical setting: a comparison with verbal rating scales in postoperative pain. Methods & Findings in Experimental & Clinical Pharmacology. 1989;11(2):123-7.
3 Gould TH, Crosby DL, Harmer M, Lloyd SM, Lunn JN, Rees GA, et al. Policy for controlling pain after surgery: effect of sequential changes in management. BMJ. 1992;305(6863):1187-93. [pmid: 1467721].
4 Walder B, Schafer M, Henzi I, Tramer MR. Efficacy and safety of patient-controlled opioid analgesia for acute postoperative pain. A quantitative systematic review. Acta Anaesthesiologica Scandinavica. 2001;45(7):795-804. [pmid: 11472277].
5 Halbert J, Crotty M. Evidence for the optimal management of acute and chronic phantom pain: a systematic review. Clin J Pain. 2002;18(2):84-92. [pmid: 11882771].
6 Bone M, Critchley P, Buggy DJ. Gabapentin in postamputation phantom limb pain: a randomized, double-blind, placebo-controlled, cross-over study. Regional Anesthesia & Pain Medicine. 2002;27(5):481-6. [pmid: 12373695].
7 Macintyre PE. Safety and efficacy of patient-controlled analgesia. British Journal of Anaesthesia. 2001;87(1):36-46. [pmid: 11460812].
8 Gehling M, Tryba M. Prophylaxis of phantom pain: is regional analgesia ineffective?. Schmerz. 2003;17(1):11-9. [pmid: 12579385].
9 Dertwinkel R, Henrichs C, Senne I, Tegenthoff M, Weiss T, Malin J, et al. Prevention of severe phantom limb pain by perioperative administration of ketamine - an observational study. Acute Pain. 2002;4:9-13.
10 Hayes C, Armstrong-Brown A, Burstal R. Perioperative intravenous ketamine infusion for the prevention of persistent post-amputation pain: a randomized, controlled trial. Anaesthesia & Intensive Care. 2004;32(3):330-8. [pmid: 15264726].
11 Jaeger H, Maier C. Calcitonin in phantom limb pain: a double-blind study. Pain. 1992;48(1):21-7. [pmid: 1738570].
12 Nikolajsen L, Hansen CL, Nielsen J, Keller J, Arendt-Nielsen L, Jensen TS. The effect of ketamine on phantom pain: a central neuropathic disorder maintained by peripheral input. Pain. 1996;67(1):69-77. [pmid: 8895233].
13 Huse E, Larbig W, Flor H, Birbaumer N. The effect of opioids on phantom limb pain and cortical reorganization. Pain. 2001;90(1–2):47-55. [pmid: 11166969].
14 Wu CL, Tella P, Staats PS, Vaslav R, Kazim DA, Wesselmann U, et al. Analgesic effects of intravenous lidocaine and morphine on postamputation pain: a randomized double-blind, active placebo-controlled, crossover trial. Anesthesiology. 2002;96(4):841-8. [pmid: 11964590].
15 Flor H, Denke C, Schaefer M, Grusser S. Effect of sensory discrimination training on cortical reorganisation and phantom limb pain. Lancet. 2001;357(9270):1763-4. [pmid: 11403816].
16 Sherman RA, Sherman CJ, Gall NG. A survey of current phantom limb pain treatment in the United States. Pain. 1980;8:85-99. [pmid: 6988765].
17 Lambert A, Dashfield A, Cosgrove C, Wilkins D, Walker A, Ashley S. Randomized prospective study comparing preoperative epidural and intraoperative perineural analgesia for the prevention of postoperative stump and phantom limb pain following major amputation. Regional Anesthesia & Pain Medicine. 2001;26(4):316-21. [pmid: 11464349].
18 Pinzur MS, Garla PG, Pluth T, Vrbos L. Continuous postoperative infusion of a regional anesthetic after an amputation of the lower extremity. A randomized clinical trial. Journal of Bone & Joint Surgery - American Volume. 1996;78(10):1501-5.
19 Chibnall JT, Tait RC. Pain assessment in cognitively impaired and unimpaired older adults: a comparison of four scales. Pain. 2001;92(1–2):173-86. [pmid: 11323138].
20 Herr KA, Spratt K, Mobily PR, Richardson G. Pain intensity assessment in older adults: use of experimental pain to compare psychometric properties and usability of selected pain scales with younger adults. Clinical Journal of Pain. 2004;20(4):207-19. [pmid: 15218405].
21 Rapp SE, Ready LB, Nessly ML. Acute pain management in patients with prior opioid consumption: a case-controlled retrospective review. Pain. 1995;61(2):195-201. [pmid: 7659429].
22 Eilers H, Philip LA, Bickler PE, McKay WR, Schumacher MA. The reversal of fentanyl-induced tolerance by administration of “small-dose” ketamine. Anesthesia & Analgesia. 2001;93(1):213-4. [pmid: 11429368].
23 Mitra S, Sinatra RS. Perioperative management of acute pain in the opioid-dependent patient. Anesthesiology. 2004;101(1):212-27. [pmid: 15220793].
24 Wang JK, Nauss LA, Thomas JE. Pain relief by intrathecally applied morphine in man. Anesthesiology. 1979;50(2):149-51. [pmid: 373503].
25 de Leon-Casasola OA, Myers DP, Donaparthi S, Bacon DR, Peppriell J, Rempel J, et al. A comparison of postoperative epidural analgesia between patients with chronic cancer taking high doses of oral opioids versus opioid-naive patients. Anesthesia & Analgesia. 1993;76(2):302-7. [pmid: 8424506].
26 Doverty M, Somogyi AA, White JM, Bochner F, Beare CH, Menelaou A, et al. Methadone maintenance patients are cross-tolerant to the antinociceptive effects of morphine. Pain. 2001;93(2):155-63. [pmid: 11427327].
27 Bell RF. Low-dose subcutaneous ketamine infusion and morphine tolerance. Pain. 1999;83(1):101-3. [pmid: 10506678].
28 Sator-Katzenschlager S, Deusch E, Maier P, Spacek A, Kress HG. The long-term antinociceptive effect of intrathecal S(+)-ketamine in a patient with established morphine tolerance. Anesthesia & Analgesia. 2001;93(4):1032-4. [pmid: 11574378].
29 Herr K, Bjoro K, Decker S. Tools for assessment of pain in nonverbal older adults with dementia: a state-of-the-science review. Journal of Pain & Symptom Management. 2006;31(2):170-92. [pmid: 16488350].
30 Fuchs-Lacelle S, Hadjistavropoulos T. Development and preliminary validation of the pain assessment checklist for seniors with limited ability to communicate (PACSLAC). Pain Management Nursing. 2004;5(1):37-49. [pmid: 14999652].
31 Villanueva MR, Smith TL, Erickson JS, Lee AC, Singer CM. Pain Assessment for the Dementing Elderly (PADE): reliability and validity of a new measure. Journal of the American Medical Directors Association. 2003;4(1):1-8. [pmid: 12807590].
32 Warden V, Hurley AC, Volicer L. Development and psychometric evaluation of the Pain Assessment in Advanced Dementia (PAINAD) scale. Journal of the American Medical Directors Association. 2003;4(1):9-15. [pmid: 12807591].
33 Abbey J, Piller N, De Bellis A, Esterman A, Parker D, Giles L, et al. The Abbey pain scale: a 1-minute numerical indicator for people with end-stage dementia. International Journal of Palliative Nursing. 2004;10(1):6-13. [pmid: 14966439].
34 Hurley AC, Volicer BJ, Hanrahan PA, Houde S, Volicer L. Assessment of discomfort in advanced Alzheimer patients. Research in Nursing & Health. 1992;15(5):369-77. [pmid: 1529121].
35 Lefebvre-Chapiro S, Doloplus Group T. The Doloplus 2 scale - evaluating pain in the elderly. Eur J Palliat Care. 2001;8:191-194.
36 Merkel SI, Voepel-Lewis T, Shayevitz JR, Malviya S. The FLACC: a behavioral scale for scoring postoperative pain in young children. Pediatric Nursing. 1997;23(3):293-7. [pmid: 9220806].
37 Snow AL, Weber JB, O’Malley KJ, Cody M, Beck C, Bruera E, et al. NOPPAIN: a nursing assistant-administered pain assessment instrument for use in dementia. Dementia & Geriatric Cognitive Disorders. 2004;17(3):240-6. [pmid: 14745230].
38 Feldt KS. The checklist of nonverbal pain indicators (CNPI). Pain Management Nursing. 2000;1(1):13-21. [pmid: 11706452].
39 Kovach CR, Weissman DE, Griffie J, Matson S, Muchka S. Assessment and treatment of discomfort for people with late-stage dementia. Journal of Pain & Symptom Management. 1999;18(6):412-9. [pmid: 10641467].
40 van Herk R, van Dijk M, Baar FP, Tibboel D, de Wit R. Observation scales for pain assessment in older adults with cognitive impairments or communication difficulties. Nurs Res. 2007;56(1):34-43. [pmid: 17179872].
41 Decker SA, Perry AG. The development and testing of the PATCOA to assess pain in confused older adults. Pain Management Nursing. 2003;4(2):77-86. [pmid: 12836152].
42 Lane P, Kuntupis M, MacDonald S, McCarthy P, Panke JA, Warden V, et al. A pain assessment tool for people with advanced Alzheimer’s and other progressive dementias. Home Healthcare Nurse. 2003;21(1):32-7. [pmid: 12544460].
43 Baker A, Bowring L, Brignell A, Kafford D. Chronic pain management in cognitively impaired patients: a preliminary research project. Perspectives. 1996;20(2):4-8. [pmid: 8900744].
44 Ekman P, Friesen W. Investigator’s guide to the Facial Action Coding System. Palo Alto. Consulting Psychologists Press. 1978.
45 Keefe F, Block A. Development of an observation method for assessing pain behavior in chronic low back pain patients. Behavior Therapy. 1982;13:363-375.
46 Zwakhalen SMG, Hamers JPH, Abu-Saad HH, Berger MPF. Pain in elderly people with severe dementia: a systematic review of behavioural pain assessment tools. BMC Geriatrics. 2006;6:3. [pmid: 16441889].
47 Davies E, Male M, Reimer V, Turner M. Pain assessment and cognitive impairment: part 2. Nurs Stand. 2004;19(13):33-40. [pmid: 15624384].
48 Wary B. Collectief Doloplus. Doloplus-2, une échelle pour évaluer la douleur. Soins Gérontologie. 1999;19:25-27.
49 Morello R, Jean A, Alix M. LÉCPA: une échelle comportementale de la douleur pour personnes âgées non communicantes InfoKara. 1998;51(3):22-29.
50 Le Quintrec JL, Maga M, Baulon A. L'échelle comportementale simplifiée (E.C.S.). La Revue de Gériatrie. 1995;20(6):363-368.
51 Sign B, Orrell M. The development, validity and reliability of a new scale for rating pain in dementia (RaPID). Unpublished manuscript. 2003.
52 Simons W, Malabar R. Assessing pain in elderly patients who cannot respond verbally. Journal of Advanced Nursing. 1995;22(4):663-9. [pmid: 8708184].
53 Merlin T, Hodgkinson B, Macintyre PE, Ludbrook G, Hiller JE. Institutional approaches to pain assessment and management (008PAI). A systematic literature review. Health Technology Assessment Database. 2003(1).
54 Miaskowski C, Crews J, Ready LB, Paul SM, Ginsberg B. Anesthesia-based pain services improve the quality of postoperative pain management. Pain. 1999;80(1–2):23-9. [pmid: 10204714].
55 Benjamin LJ, Swinson GI, Nagel RL. Sickle cell anemia day hospital: an approach for the management of uncomplicated painful crises. Blood. 2000;95(4):1130-6. [pmid: 10666181].
56 Ahles TA, Seville J, Wasson J, Johnson D, Callahan E, Stukel TA. Panel-based pain management in primary care. a pilot study. Journal of Pain & Symptom Management. 2001;22(1):584-90. [pmid: 11516600].
57 McQuillar R, Finlay I, Roberts D, Branch C, Forbes K, Spencer MG. The provision of a palliative care service in a teaching hospital and subsequent evaluation of that service. Palliative Medicine. 1996;10(3):231-9. [pmid: 8817594].
58 Tighe SQ, Bie JA, Nelson RA, Skues MA. The acute pain service: effective or expensive care?. Anaesthesia. 1998;53(4):397-403. [pmid: 9613309].
59 Mackintosh C, Bowles S. Evaluation of a nurse-led acute pain service. Can clinical nurse specialists make a difference?. Journal of Advanced Nursing. 1997;25(1):30-7. [pmid: 9004008].
60 Sartain JB, Barry JJ. The impact of an acute pain service on postoperative pain management. Anaesthesia & Intensive Care. 1999;27(4):375-80. [pmid: 10470392].
61 Bardiau FM, Braeckman MM, Seidel L, Albert A, Boogaerts JG. Effectiveness of an acute pain service inception in a general hospital. Journal of Clinical Anesthesia. 1999;11(7):583-9. [pmid: 10624644].
62 Pesut B, Johnson J. Evaluation of an acute pain service. Canadian Journal of Nursing Administration. 1997;10(4):86-107. [pmid: 9450414].
63 Ranji SR, Goldman LE, Simel DL, Shojania KG. Do opiates affect the clinical evaluation of patients with acute abdominal pain?. JAMA. 2006;296(14):1764-74. [pmid: 17032990].
64 Attard AR, Corlett MJ, Kidner NJ, Leslie AP, Fraser IA. Safety of early pain relief for acute abdominal pain. BMJ. 1992;305:554-556. [pmid: 1393034].
65 Pace S, Burke T. Intravenous morphine for early pain relief in patients with acute abdominal pain. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. 1996;3(12):1086-92. [pmid: 8959160].
66 Mahadevan M, Graff L. Prospective randomized study of analgesic use for ED patients with right lower quadrant abdominal pain. American Journal of Emergency Medicine. 2000;18(7):753-6. [pmid: 11103723].
67 Attard AR, Corlett MJ, Kidner NJ, Leslie AP, Fraser IA. Safety of early pain relief for acute abdominal pain. BMJ. 1992;305(6853):554-6. [pmid: 1393034].
68 LoVecchio F, Oster N, Sturmann K, Nelson LS, Flashner S, Finger R. The use of analgesics in patients with acute abdominal pain. Journal of Emergency Medicine. 1997;15(6):775-9. [pmid: 9404792].
69 Garyfallou GT, Grillo A, O’Connor RE, Fulda GJ, Levine BJ. A controlled trial of fentanyl analgesia in emergency department patients with abdominal pain: can treatment obscure the diagnosis?. Acad Emerg Med. 1997;4:424.
70 Vermeulen B, Morabia A, Unger PF, Goehring C, Grangier C, Skljarov I, et al. Acute appendicitis: influence of early pain relief on the accuracy of clinical and US findings in the decision to operate--a randomized trial. Radiology. 1999;210(3):639-43. [pmid: 10207461].
71 Wolfe JM, Smithline HA, Phipen S, Montano G, Garb JL, Fiallo V. Does morphine change the physical examination in patients with acute appendicitis?. American Journal of Emergency Medicine. 2004;22(4):280-5. [pmid: 15258869].
72 Thomas SH, Silen W, Cheema F, Reisner A, Aman S, Goldstein JN, et al. Effects of morphine analgesia on diagnostic accuracy in Emergency Department patients with abdominal pain: a prospective, randomized trial. Journal of the American College of Surgeons. 2003;196(1):18-31. [pmid: 12517545].
73 Holdgate A, Pollock T. Nonsteroidal anti-inflammatory drugs (NSAIDS) versus opioids for acute renal colic. Cochrane Database of Systematic Reviews. 2007(2).
74 Uden P, Rentzhog L, Berger T. A comparative study on the analgesic effects of indomethacin and hydromorphinechloride-atropine in acute, ureteral-stone pain. Acta Chir Scand. 1983;149(5):497-9. [pmid: 6637313].
75 Quilez C, Perez-Mateo M, Hernandez P, Rubio I. Usefulness of a non-steroid anti-inflammatory, sodium diclofenac, in the treatment of renal colic. Comparative study with a spasmolytic and an opiate analgesic. Med Clin (Barc). 1984;82(17):754-5. [pmid: 6738191].
76 Lundstam SO, Leissner KH, Wahlander LA, Kral JG. Prostaglandin-synthetase inhibition with diclofenac sodium in treatment of renal colic: comparison with use of a narcotic analgesic. Lancet. 1982;1(8281):1096-7. [pmid: 6122892].
77 Lehtonen T, Kellokumpu I, Permi J, Sarsila O. Intravenous indomethacin in the treatment of ureteric colic. A clinical multicentre study with pethidine and metamizol as the control preparations. Ann Clin Res. 1983;15(5–6):197-9. [pmid: 6364951].
78 Persson NH, Bergqvist D, Melander A, Zederfelt B. Comparison of a narcotic (oxicone) and a non-narcotic anti-inflammatory analgesic (indoprofen) in the treatment of renal colic. Acta Chir Scand. 1985;151(2):105-8. [pmid: 3890435].
79 Hetherington JW, Philp NH. Diclofenac sodium versus pethidine in acute renal colic. Br Med J (Clin Res Ed). 1986;292(6515):237-8.
80 Jonsson PE, Olsson AM, Petersson BA, Johansson K. Intravenous indomethacin and oxycone-papaverine in the treatment of acute renal colic. A double-blind study. Br J Urol. 1987;59(5):396-400. [pmid: 3297230].
81 Thompson JF, Pike JM, Chumas PD, Rundle JS. Rectal diclofenac compared with pethidine injection in acute renal colic. Bmj. 1989;299(6708):1140-1. [pmid: 2513026].
82 Oosterlinck W, Philp NH, Charig C, Gillies G, Hetherington JW, Lloyd J. A double-blind single dose comparison of intramuscular ketorolac tromethamine and pethidine in the treatment of renal colic. J Clin Pharmacol. 1990;30(4):336-41. [pmid: 2341581].
83 Arnau JM, Cami J, Garcia-Alonso F, Laporte JR, Palop R. Comparative study of the efficacy of dipyrone, diclofenac sodium and pethidine in acute renal colic. Collaborative Group of the Spanish Society of Clinical Pharmacology. Eur J Clin Pharmacol. 1991;40(6):543-6. [pmid: 1884733].
84 Marthak KV, Gokarn AM, Rao AV, Sane SP, Mahanta RK, Sheth RD, et al. A multi-centre comparative study of diclofenac sodium and a dipyrone/spasmolytic combination, and a single-centre comparative study of diclofenac sodium and pethidine in renal colic patients in India. Curr Med Res Opin. 1991;12(6):366-73. [pmid: 2044396].
85 Cordell WH, Larson TA, Lingeman JE, Nelson DR, Woods JR, Burns LB, et al. Indomethacin suppositories versus intravenously titrated morphine for the treatment of ureteral colic. Ann Emerg Med. 1994;23(2):262-9. [pmid: 8304606].
86 Sandhu DP, Iacovou JW, Fletcher MS, Kaisary AV, Philip NH, Arkell DG. A comparison of intramuscular ketorolac and pethidine in the alleviation of renal colic. Br J Urol. 1994;74(6):690-3. [pmid: 7827834].
87 Curry C, Kelly AM. Intravenous tenoxicam for the treatment of renal colic. N Z Med J. 1995;108(1001):229-30. [pmid: 7603654].
88 Cordell WH, Wright SW, Wolfson AB, Timerding BL, Maneatis TJ, Lewis RH, et al. Comparison of intravenous ketorolac, meperidine, and both (balanced analgesia) for renal colic. Ann Emerg Med. 1996;28(2):151-8. [pmid: 8759578].
89 al-Sahlawi KS, Tawfik OM. Comparative study of the efficacy of lysine acetylsalicylate, indomethacin and pethidine in acute renal colic. Eur J Emerg Med. 1996;3(3):183-6. [pmid: 9023498].
90 Larkin GL, Peacock WFt, Pearl SM, Blair GA, D’Amico F. Efficacy of ketorolac tromethamine versus meperidine in the ED treatment of acute renal colic. Am J Emerg Med. 1999;17(1):6-10. [pmid: 9928687].
91 Torralba NJA, Montiel RM, Perez BV, Nadal VP, Albacete PM. [Intramuscular ketorolac compared to subcutaneous tramadol in the initial emergency treatment of renal colic]. Arch Esp Urol. 1999;52(5):435-7. [pmid: 10427881].
92 Sommer P, Kromann-Andersen B, Lendorf A, Lyngdorf P, Moller P. Analgesic effect and tolerance of Voltaren and Ketogan in acute renal or ureteric colic. Br J Urol. 1989;63(1):4-6. [pmid: 2645969].
93 Tramer MR, Williams JE, Carroll D, Wiffen PJ, Moore RA, McQuay HJ. Comparing analgesic efficacy of non-steroidal anti-inflammatory drugs given by different routes in acute and chronic pain: a qualitative systematic review. Acta Anaesthesiologica Scandinavica. 1998;42(1):71-9. [pmid: 9527748].
94 Muriel-Villoria C, Zungri-Telo E, Diaz-Curiel M, Fernandez-Guerrero M, Moreno J, Puerta J, et al. Comparison of the onset and duration of the analgesic effect of dipyrone, 1 or 2 g, by the intramuscular or intravenous route, in acute renal colic. European Journal of Clinical Pharmacology. 1995;48(2):103-7. [pmid: 7589022].
95 Nelson CE, Nylander C, Olsson AM, Olsson R, Pettersson BA, Wallstrom I. Rectal v. intravenous administration of indomethacin in the treatment of renal colic. Acta Chirurgica Scandinavica. 1988;154(4):253-5. [pmid: 3287813].
96 Nissen I, Birke H, Olsen JB, Wurtz E, Lorentzen K, Salomon H, et al. Treatment of ureteric colic. Intravenous versus rectal administration of indomethacin. British Journal of Urology. 1990;65(6):576-9. [pmid: 2196971].
97 Quigley C. Hydromorphone for acute and chronic pain. Cochrane Database of Systematic Reviews. 2007(2).
98 Jasani NB, O’Conner RE, Bouzoukis JK. Comparison of hydromorphone and meperidine for ureteral colic. Academic Emergency Medicine. 1994;1(6):539-43. [pmid: 7541310].
99 Uden P, Starck CJ, Berger T. Comparison of indomethacin and dihydromorphinone in acute, biliary stone pain. Current Ther Res. 1984;36(6):1228-34.
100 Goldberg GR, Morrison RS. Pain management in hospitalized cancer patients: a systematic review’. J Clin Oncology. 2007;25(13):1792-1801.
101 de Rond ME, de Wit R, van Dam FS, Muller MJ. A Pain Monitoring Program for nurses: effect on the administration of analgesics. Pain. 2000;89(1):25-38. [pmid: 11113290].
102 Ward SE, Gordon DB. Patient satisfaction and pain severity as outcomes in pain management: a longitudinal view of one setting’s experience. Journal of Pain & Symptom Management. 1996;11(4):242-51. [pmid: 8869459].
103 Bookbinder M, Blank AE, Arney E, Wollner D, Lesage P, McHugh M, et al. Improving end-of-life care: development and pilot-test of a clinical pathway. Journal of Pain & Symptom Management. 2005;29(6):529-43. [pmid: 15963861].
104 de Rond ME, de Wit R, van Dam FS, Muller MJ. A pain monitoring program for nurses: effects on communication, assessment and documentation of patients’ pain. Journal of Pain & Symptom Management. 2000;20(6):424-39. [pmid: 11131261].
105 de Rond M, de Wit R, van Dam F. The implementation of a Pain Monitoring Programme for nurses in daily clinical practice: results of a follow-up study in five hospitals. Journal of Advanced Nursing. 2001;35(4):590-8. [pmid: 11529959].
106 Bach S, Noreng MF, Tjellden NU. Phantom limb pain in amputees during the first 12 months following limb amputation, after preoperative lumbar epidural blockade. Pain. 1988;33(3):297-301. [pmid: 3419837].
107 Lundeberg T. Relief of pain from a phantom limb by peripheral stimulation. Journal of Neurology. 1985;232(2):79-82. [pmid: 2410571].
108 Jahangiri M, Jayatunga AP, Bradley JW, Dark CH. Prevention of phantom pain after major lower limb amputation by epidural infusion of diamorphine, clonidine and bupivacaine. Annals of the Royal College of Surgeons of England. 1994;76(5):324-6. [pmid: 7979074].
109 Nikolajsen L, Ilkjaer S, Christensen JH, Kroner K, Jensen TS. Randomised trial of epidural bupivacaine and morphine in prevention of stump and phantom pain in lower-limb amputation. Lancet. 1997;350(9088):1353-7. [pmid: 9365449].
110 Conine TA, Hershler C, Alexander ST, Crisp R. The efficacy of Farabloc in the treatment of phantom limb pain. Can J Rehabil. 1993;6:155-61.
111 Katz J, Melzack R. Auricular transcutaneous electrical nerve stimulation (TENS) reduces phantom limb pain. Journal of Pain & Symptom Management. 1991;6(2):73-83. [pmid: 2007795].
112 Elizaga AM, Smith DG, Sharar SR, Edwards WT, Hansen ST Jr. Continuous regional analgesia by intraneural block: effect on postoperative opioid requirements and phantom limb pain following amputation. Journal of Rehabilitation Research & Development. 1994;31(3):179-87. [pmid: 7965876].
113 Fisher A, Meller Y. Continuous postoperative regional analgesia by nerve sheath block for amputation surgery--a pilot study. Anesthesia & Analgesia. 1991;72(3):300-3. [pmid: 1994757].
114 Finsen V, Persen L, Lovlien M, Veslegaard EK, Simensen M, Gasvann AK, et al. Transcutaneous electrical nerve stimulation after major amputation. Journal of Bone & Joint Surgery - British Volume. 1988;70(1):109-12. [pmid: 3257494].