# References

1 Senate: Veterans’ Affairs Committee. S. 2484 (108th Congress): Department of Veterans Affairs Health Care Personnel Enhancement Act of 2004. December 3 2004.
2 Clough JD, McClellan M. Implementing MACRA: Implications for Physicians and for Physician Leadership. JAMA. 2016;315(22):2397–2398.27213914
3 Kondo K, Damberg C, Mendelson A, Understanding the Intervention and Implementation Factors Associated with Benefits and Harms of Pay for Performance Programs in Healthcare. Washington, DC: Department of Veterans Affairs; 2015.
4 Kondo KK, Damberg CL, Mendelson A, Implementation processes and pay for performance in healthcare: A systematic review. J Gen Intern Med. 2016;31(Suppl 1):61–69.26951276
5 Mendelson A, Kondo K, Damberg C, The Effects of Pay-for-Performance Programs on Health, Health Care Use, and Processes of Care: A Systematic Review. Ann Intern Med. 2017;166(5):341–353.28114600
6 Department of Veterans Affairs. VHA Office of Community Care. Available at https://www.va.gov/purchasedcare/. Accessed March 24, 2017.
7 Commission on Care. Final Report of the Commission on Care. 2016.
8 Hsieh HF, Shannon SE. Three approaches to qualitative content analysis. Qual Health Res. 2005;15(9):1277–1288.16204405
9 Higgins J, Green S. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. 2011; http://handbook.cochrane.org/. Accessed March 24, 2017.
10 Wells GA, Shea B, O’Connell D, The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomized studies in meta-analyses. Available at http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed March 24, 2017.
11 Herzog R, Alvarez-Pasquin MJ, Diaz C, Del Barrio JL, Estrada JM, Gil A. Are healthcare workers’ intentions to vaccinate related to their knowledge, beliefs and attitudes? A systematic review. BMC Public Health. 2013;13(1):17.23302300
12 Damschroder LJ, Aron DC, Keith RE, Kirsh SR, Alexander JA, Lowery JC. Fostering implementation of health services research findings into practice: a consolidated framework for advancing implementation science. Implement Sci. 2009;4:50.19664226
13 Berkman N, Lohr K, Ansari M, Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. 2013; http://www.effectivehealthcare.ahrq.gov/ehc/products/457/1752/methods-guidance-grading-evidence-131118.pdf. Accessed December 28, 2016.
14 Benzer JK, Young GJ, Burgess JF, Sustainability of quality improvement following removal of pay-for-performance incentives. J Gen Intern Med. 2014;29(1):127–132.23929219
15 Harris AH, Chen C, Rubinsky AD, Hoggatt KJ, Neuman M, Vanneman ME. Are Improvements in Measured Performance Driven by Better Treatment or “Denominator Management”? J Gen Intern Med. 2016;31 Suppl 1:21–27.26951270
16 Petersen LA, Ramos KS, Pietz K, Woodard LD. Impact of a Pay-for-Performance Program on Care for Black Patients with Hypertension: Important Answers in the Era of the Affordable Care Act. Health Serv Res. 2016.
17 Petersen LA, Simpson K, Pietz K, Effects of individual physician-level and practice-level financial incentives on hypertension care: a randomized trial. JAMA. 2013;310(10):1042–1050.24026599
18 Urech TH, Woodard LD, Virani SS, Dudley RA, Lutschg MZ, Petersen LA. Calculations of Financial Incentives for Providers in a Pay-for-Performance Program: Manual Review Versus Data From Structured Fields in Electronic Health Records. Med Care. 2015;53(10):901–907.26340661
19 Kansagara D, Tuepker A, Joos S, Nicolaidis C, Skaperdas E, Hickam D. Getting performance metrics right: a qualitative study of staff experiences implementing and measuring practice transformation. J Gen Intern Med. 2014;29 Suppl 2:S607–613.24557515
20 Damschroder LJ, Robinson CH, Francis J, Effects of performance measure implementation on clinical manager and provider motivation. J Gen Intern Med. 2014;29 Suppl 4:877–884.25234554
21 Beard AJ, Hofer TP, Downs JR, Assessing appropriateness of lipid management among patients with diabetes mellitus: moving from target to treatment. Circ Cardiovasc Qual Outcomes. 2013;6(1):66–74.23233749
22 Kerr EA, Lucatorto MA, Holleman R, Hogan MM, Klamerus ML, Hofer TP. Monitoring performance for blood pressure management among patients with diabetes mellitus: too much of a good thing? Arch Intern Med. 2012;172(12):938–945.22641246
23 Petersen LA, Woodard LD, Henderson LM, Urech TH, Pietz K. Will hypertension performance measures used for pay-for-performance programs penalize those who care for medically complex patients? Circulation. 2009;119(23):2978–2985.19487595
24 Saini SD, Powell AA, Dominitz JA, Developing and Testing an Electronic Measure of Screening Colonoscopy Overuse in a Large Integrated Healthcare System. J Gen Intern Med. 2016;31 Suppl 1:53–60.26951277
25 Saini SD, Vijan S, Schoenfeld P, Powell AA, Moser S, Kerr EA. Role of quality measurement in inappropriate use of screening for colorectal cancer: retrospective cohort study. BMJ. 2014;348:g1247.24574474
26 Powell AA, White KM, Partin MR, Unintended consequences of implementing a national performance measurement system into local practice. J Gen Intern Med. 2012;27(4):405–412.21993998
27 Powell AA, White KM, Partin MR, More than a score: a qualitative study of ancillary benefits of performance measurement. BMJ Qual Saf. 2014;23(8):651–658.
28 Hysong SJ, SoRelle R, Broussard Smitham K, Petersen LA. Reports of unintended consequences of financial incentives to improve management of hypertension. PLoS One. 2017;12(9):e0184856.28934258
29 Greene J. An examination of pay-for-performance in general practice in Australia. Health Serv Res. 2013;48(4):1415–1432.23350933
30 Ryan AM, Burgess JF, Jr., Pesko MF, Borden WB, Dimick JB. The early effects of Medicare’s mandatory hospital pay-for-performance program. Health Serv Res. 2015;50(1):81–97.25040485
31 Kalwij S, French S, Mugezi R, Baraitser P. Using educational outreach and a financial incentive to increase general practices’ contribution to chlamydia screening in South-East London 2003–2011. BMC Public Health. 2012;12:802.22984897
32 Rat C, Penhouet G, Gaultier A, Did the new French pay-for-performance system modify benzodiazepine prescribing practices? BMC Health Serv Res. 2014;14:301.25011548
33 Torchiana DF, Colton DG, Rao SK, Lenz SK, Meyer GS, Ferris TG. Massachusetts General Physicians Organization’s quality incentive program produces encouraging results. Health Aff (Millwood). 2013;32(10):1748–1756.24101064
34 Esse T, Serna O, Chitnis A, Johnson M, Fernandez N. Quality compensation programs: are they worth all the hype? A comparison of outcomes within a Medicare advantage heart failure population. J Manag Care Pharm. 2013;19(4):317–324.23627577
35 Kirschner K, Braspenning J, Akkermans RP, Jacobs JE, Grol R. Assessment of a pay-for-performance program in primary care designed by target users. Fam Pract. 2013;30(2):161–171.22997223
36 Martens JD, Werkhoven MJ, Severens JL, Winkens RA. Effects of a behaviour independent financial incentive on prescribing behaviour of general practitioners. J Eval Clin Pract. 2007;13(3):369–373.17518801
37 Pechlivanoglou P, Wieringa JE, de Jager T, Postma MJ. The effect of financial and educational incentives on rational prescribing. A state-space approach. Health Econ. 2015;24(4):439–453.24519732
38 Kantarevic J, Kralj B. Link between pay for performance incentives and physician payment mechanisms: evidence from the diabetes management incentive in Ontario. Health Econ. 2013;22(12):1417–1439.23203722
39 Li J, Hurley J, DeCicca P, Buckley G. Physician response to pay-for-performance: evidence from a natural experiment. Health Econ. 2014;23(8):962–978.23861240
40 Kruse GR, Chang Y, Kelley JH, Linder JA, Einbinder JS, Rigotti NA. Healthcare system effects of pay-for-performance for smoking status documentation. Am J Manag Care. 2013;19(7):554–561.23919419
41 Andriole KP, Prevedello LM, Dufault A, Augmenting the impact of technology adoption with financial incentive to improve radiology report signature times. J Am Coll Radiol. 2010;7(3):198–204.20193925
42 Colais P, Pinnarelli L, Fusco D, Davoli M, Braga M, Perucci CA. The impact of a payfor-performance system on timing to hip fracture surgery: experience from the Lazio Region (Italy). BMC Health Serv Res. 2013;13:393.24099264
43 Young GJ, Beckman HB, Baker E. Financial incentives, professional values and performance: A study of pay-for-performance in a professional organization. Journal of Organizational Behavior. 2012;33(7):964–983.
44 Chang RE, Lin SP, Aron DC. A pay-for-performance program in Taiwan improved care for some diabetes patients, but doctors may have excluded sicker ones. Health Aff (Millwood). 2012;31(1):93–102.22232099
45 Lai CL, Hou YH. The association of clinical guideline adherence and pay-for-performance among patients with diabetes. J Chin Med Assoc. 2013;76(2):102–107.23351421
46 Lee TT, Cheng SH, Chen CC, Lai MS. A pay-for-performance program for diabetes care in Taiwan: a preliminary assessment. Am J Manag Care. 2010;16(1):65–69.20148607
47 Chen CS, Liu TC, Chen B, Lin CL. The failure of financial incentive? The seemingly inexorable rise of cesarean section. Soc Sci Med. 2014;101:47–51.24560223
48 Li YH, Tsai WC, Khan M, The effects of pay-for-performance on tuberculosis treatment in Taiwan. Health Policy Plan. 2010;25(4):334–341.20207703
49 Kristensen SR, Meacock R, Turner AJ, Long-term effect of hospital pay for performance on mortality in England. N Engl J Med. 2014;371(6):540–548.25099578
50 Karunaratne K, Stevens P, Irving J, The impact of pay for performance on the control of blood pressure in people with chronic kidney disease stage 3–5. Nephrol Dial Transplant. 2013;28(8):2107–2116.23658247
51 Arrowsmith ME, Majeed A, Lee JT, Saxena S. Impact of pay for performance on prescribing of long-acting reversible contraception in primary care: an interrupted time series study. PLoS One. 2014;9(4):e92205.24694949
52 Doran T, Kontopantelis E, Valderas JM, Effect of financial incentives on incentivised and non-incentivised clinical activities: longitudinal analysis of data from the UK Quality and Outcomes Framework. BMJ. 2011;342:d3590.21712336
53 Kontopantelis E, Springate D, Reeves D, Ashcroft DM, Valderas JM, Doran T. Withdrawing performance indicators: retrospective analysis of general practice performance under UK Quality and Outcomes Framework. BMJ. 2014;348:g330.24468469
54 Millett C, Bottle A, Ng A, Pay for perfomance and the quality of diabetes management in individuals with and without co-morbid medical conditions. J R Soc Med. 2009;102(9):369–377.19734534
55 Millett C, Gray J, Saxena S, Netuveli G, Majeed A. Impact of a pay-for-performance incentive on support for smoking cessation and on smoking prevalence among people with diabetes. CMAJ. 2007;176(12):1705–1710.17548383
56 Norbury M, Fawkes N, Guthrie B. Impact of the GP contract on inequalities associated with influenza immunisation: a retrospective population-database analysis. Br J Gen Pract. 2011;61(588):e379–385.21722444
57 Szatkowski L, McNeill A, Lewis S, Coleman T. A comparison of patient recall of smoking cessation advice with advice recorded in electronic medical records. BMC Public Health. 2011;11:291.21569283
58 Taggar JS, Coleman T, Lewis S, Szatkowski L. The impact of the Quality and Outcomes Framework (QOF) on the recording of smoking targets in primary care medical records: cross-sectional analyses from The Health Improvement Network (THIN) database. BMC Public Health. 2012;12:329.22559290
59 Tahrani AA, McCarthy M, Godson J, Diabetes care and the new GMS contract: the evidence for a whole county. Br J Gen Pract. 2007;57(539):483–485.17550674
60 MacBride-Stewart SP, Elton R, Walley T. Do quality incentives change prescribing patterns in primary care? An observational study in Scotland. Fam Pract. 2008;25(1):27–32.18245796
61 Kontopantelis E, Reeves D, Valderas JM, Campbell S, Doran T. Recorded quality of primary care for patients with diabetes in England before and after the introduction of a financial incentive scheme: a longitudinal observational study. BMJ Qual Saf. 2013;22(1):53–64.
62 Simpson CR, Hannaford PC, Ritchie LD, Sheikh A, Williams D. Impact of the pay-for-performance contract and the management of hypertension in Scottish primary care: a 6-year population-based repeated cross-sectional study. Br J Gen Pract. 2011;61(588):e443–451.21722469
63 Vaghela P, Ashworth M, Schofield P, Gulliford MC. Population intermediate outcomes of diabetes under pay-for-performance incentives in England from 2004 to 2008. Diabetes Care. 2009;32(3):427–429.19106379
64 Sutton M, Elder R, Guthrie B, Watt G. Record rewards: the effects of targeted quality incentives on the recording of risk factors by primary care providers. Health Econ. 2010;19(1):1–13.
65 Kuo RN, Chung KP, Lai MS. Effect of the Pay-for-Performance Program for Breast Cancer Care in Taiwan. J Oncol Pract. 2011;7(3 Suppl):e8s–e15s.21886513
66 Frakt AB, Trafton J, Pizer SD. The association of mental health program characteristics and patient satisfaction. Am J Manag Care. 2017;23(5):e129–e137.28810128
67 Hysong SJ, Amspoker AB, Petersen LA. A Novel Method for Assessing Task Complexity in Outpatient Clinical-Performance Measures. J Gen Intern Med. 2016;31 Suppl 1:28–35.26951275
68 Hysong SJ, Khan MM, Petersen LA. Passive monitoring versus active assessment of clinical performance: impact on measured quality of care. Med Care. 2011;49(10):883–890.21918399
69 Petersen LA, Pietz K, Woodard LD, Byrne M. Comparison of the predictive validity of diagnosis-based risk adjusters for clinical outcomes. Med Care. 2005;43(1):61–67.15626935
70 Rosen AK, Chen Q, Shwartz M, Does Use of a Hospital-wide Readmission Measure Versus Condition-specific Readmission Measures Make a Difference for Hospital Profiling and Payment Penalties? Med Care. 2016;54(2):155–161.26595224
71 Prentice J, Legler A, Li D, Pizer SD. Optimizing Access Metrics in the VA. https://wwwhsrdresearchvagov/for_researchers/cyber_seminars/archives/1166-notespdf.
72 Prentice JC, Davies ML, Pizer SD. Which outpatient wait-time measures are related to patient satisfaction? Am J Med Qual. 2014;29(3):227–235.23939488
73 Hysong SJ, Simpson K, Pietz K, SoRelle R, Broussard Smitham K, Petersen LA. Financial incentives and physician commitment to guideline-recommended hypertension management. Am J Manag Care. 2012;18(10):e378–391.23145846
74 Hysong SJ, Knox MK, Haidet P. Examining clinical performance feedback in Patient-Aligned Care Teams. J Gen Intern Med. 2014;29 Suppl 2:S667–674.24715398
75 Hysong SJ, Best RG, Pugh JA. Audit and feedback and clinical practice guideline adherence: making feedback actionable. Implement Sci. 2006;1:9.16722539
76 Finley EP, Noel PH, Mader M, Community Clinicians and the Veterans Choice Program for PTSD Care: Understanding Provider Interest During Early Implementation. Med Care. 2017;55 Suppl 7 Suppl 1:S61–s70.28146035
77 Gellad WF, Cunningham FE, Good CB, Pharmacy Use in the First Year of the Veterans Choice Program: A Mixed-methods Evaluation. Med Care. 2017;55 Suppl 7 Suppl 1:S26–s32.28221274
78 Quinn M, Robinson C, Forman J, Krein SL, Rosland AM. Survey Instruments to Assess Patient Experiences With Access and Coordination Across Health Care Settings: Available and Needed Measures. Med Care. 2017;55 Suppl 7 Suppl 1:S84–s91.28614185
79 Tsai J, Yakovchenko V, Jones N, “Where’s My Choice?” An Examination of Veteran and Provider Experiences With Hepatitis C Treatment Through the Veteran Affairs Choice Program. Med Care. 2017;55 Suppl 7 Suppl 1:S13–s19.28263281
80 Zuchowski JL, Chrystal JG, Hamilton AB, Coordinating Care Across Health Care Systems for Veterans With Gynecologic Malignancies: A Qualitative Analysis. Med Care. 2017;55 Suppl 7 Suppl 1:S53–s60.28614184