# Summary and Discussion

We examined 68 articles and conducted interviews with 17 key informants to help inform the implementation of pay-for-performance programs for Veterans in the VHA and in community settings. While we found insufficient evidence to determine whether and how much P4P affects Veteran outcomes, we did find information in the literature and through KI interviews that may help guide the implementation of P4P and maximize potential benefits while minimizing negative unintended consequences

P4P programs in published literature have focused primarily on incentives for process of care/quality metrics. Other than intermediate targets such as blood pressure and cholesterol for cardiovascular health and diabetes, we identified very few incentivized patient outcomes.

## Pay-for-Performance in VHA Settings

Several themes related to general issues with P4P in the VHA emerged from key informant interviews that are consistent with the findings from published literature (see Table 12):

- Regardless of whether performance metrics are incentivized, they should be valid, achievable, and within a provider’s control. Consistent with previous findings the importance of evidence-based metrics,^3,4^ key informants felt that performance metrics should be valid and well-designed and cited a need for further research evaluating alternate validation methods.
- Potential overtreatment and overuse may be an unintended consequence of performance metrics, and de-intensification metrics should be considered. Findings from a handful of included studies^21,22,24–26^ coupled with concerns voiced by key informants, suggest that potential overtreatment and overuse may be an unintended consequence of performance metrics, regardless of whether they are incentivized – and particularly in VHA facilities that are metric-oriented.
- Consider re-evaluation of the size (monetary), frequency, and target (provider versus team) of performance pay in the VHA. Consistent with research examining P4P in the VHA,^20^ provider KIs consistently stated that they did not know which metrics were incentivized and did not feel that the current structure influences their behavior. Additionally, despite a study that found otherwise,^17^ a number of KIs proposed that the VHA consider implementing team-based incentives and incentives for other front-line staff.
- Use a transparent, bottom-up approach for selecting and implementing metrics, and secure provider and staff buy-in. Despite previous research stressing the importance of bottom-up, realistic metrics,^3,4^ VA staff describe performance metrics as poorly implemented in the VHA,^20^ and voice frustration with the current top-down methods.^19^ There was strong consensus among KIs that incentivized metrics be achievable and accompanied by the local resources necessary for achievement, that decisions regarding what to incentivize are perceived as equitable, and that incentive payments are predictable and reliable.
- Foster overall and local-level cultures that encourage learning and value quality improvement. Included studies found that metric-driven cultures were more prone to potential overtreatment.^21,22^ Similarly, one KI said, “We think of the VA as a learning organization, so a pathway is learning to do better and learning to do things that fit with the goals of the VA as an institution. You have to figure out a way of developing the learning organization in all of our facilities. If we improve that they can be successful.”
- Gaming will likely be mitigated by providing the resources support necessary for achievement. According to one KI, “Inadequate resources, unrealistic expectations, and the opportunity to cheat all are factors in gaming,” and another, “The reason you have things like gaming the system isn’t because people don’t want to do the right thing, it’s because they can’t do the right thing.” Overtreatment may also be mitigated by incentivizing appropriate care, rather than treatment or targets, as demonstrated by the single included RCT.^17^

Table 12 Evidence and Policy Implications - P4P in VHA Settings

Implementation Framework Category | Study Evidence | Themes from KI Interviews | Policy Implications
Program Design Features | Ten studies examined program design features.^17–19,24,66,67,69–72^ In general, studies found:; - Physician-targeted incentives to be more effective than those targeting practices; - The degree of agreement between EHR data and manual review varies by metric; - The difficulty of achieving multi-tasked metrics is not directly related to the number of tasks involved; - The relationship between access and patient satisfaction varies by measure and in new vs returning patients | Incentives:; - Incentives should be larger, more frequent, clinically meaningful, and within the provider’s control; - Consider incentivizing teams and other front-line staff, as well as administrative functions and patient evaluation metrics; Performance Metrics:; - Performance metrics must be valid, and alternative methods of identification and validation should be explored; - Consider de-intensification metrics to mitigate potential overtreatment; - Past access metrics have not been achievable – access relates to supply, demand, and resources | - Regardless of whether performance metrics are incentivized, they should be valid, achievable, and within a provider’s control; - Consider re-evaluation of the size (monetary), frequency, and target (provider vs team) of performance pay in the VHA.; - Potential overtreatment and overuse may be an unintended consequence of performance metrics, and de-intensification metrics should be considered.
Implementation Factors | The 8 studies^14,17,19,20,68,73–75^ examining implementation factors found:; - There was no difference in the achievement of actively vs passively monitored metrics; - The evidence related to the impact of the removal of incentives on performance is mixed; - Providers express frustration for current top-down implementation strategies, and suggest areas of improvement for implementing performance metrics at the local level; - Facilities with high adherence to clinical guidelines were more likely to deliver more timely, individualized, and non-punitive feedback; - Audit and feedback processes remained largely unchanged after PACT implementation | P4P is just one aspect of quality improvement (eg, public reporting and audit and feedback are important too) Incentives:; - VHA providers don’t know what their performance pay is linked to; - P4P at the VHA is unreliable due to the unpredictability of the budgetary allocation; Metrics:; - Metrics should align with VHA goals, and be locally achievable; - Use a bottom-up approach for choosing metrics to incentivize, or at least implement P4P in a manner people view as “fair”; - Performance metrics implementation should include clear accessible documentation that includes interpretation, a menu of approaches to achievement, technical assistance, and implementation support; Inner Setting:; - Organizational cultures that encourage learning and quality improvement are important; - Consider the facility-level context - the pathway to success for each facility is different, and may require additional resources and/or organizational change | - Use a transparent, bottom-up approach for selecting and implementing metrics, and secure provider and staff buy-in.; - Foster overall and local-level cultures that encourage learning and value quality improvement
Provider Cognition, Affect, and Behavior | One study examined provider affective/cognitive responses, and found that P4P had no impact on goal commitment.^73^ Twelve articles^15–17,19–27^ examined unintended consequences and found:; - Administrative data support the potential for over-treatment associated with performance metrics. However, a RCT found no association between P4P for hypertension and hypotension; - There was evidence of denominator management associated with a VISN Director-aimed incentive; - There was no evidence of risk selection; - Providers perceived both negative and positive unintended consequences associated with performance metrics | Physicians are primarily intrinsically, not extrinsically motivated Overtreatment:; - There is great potential for overtreatment associated with PMs and P4P, particularly in metric-driven cultures, and with intermediate outcomes that vary (eg, blood pressure); - VHA should consider placing more emphasis on prevention (eg, lifestyle counseling) and de-intensification; Denominator Management:; - Concerns related to denominator management – and challenges related to the denominator in general, given the subjective nature and variability in some diagnoses and treatment recommendations; Risk Selection/Health Disparities; - Low-SES Veterans in particularly, may be at risk for risk selection and disparities related to PMs and P4P; Teaching to the Test/Attention Shift:; - A variety of actively monitored, valid metrics covering different aspects of care/different populations may mitigate the potential for teaching to the test/attention shift; Gaming:; - History of gaming in the VHA - particularly within the context of P4P; - To mitigate gaming, PMs should be accompanied by adequate resources and support (crucial when incentivized); - Differing viewpoints about composite measures to mitigate gaming - lack of transparency, goal of improving specific metrics rather than average performance | - Potential overtreatment and overuse may be an unintended consequence of performance metrics, and de-intensification metrics should be considered.; - Gaming will likely be mitigated by providing the resources support necessary for achievement

Abbreviations: EHR = electronic health record, PACT = Patient Aligned Care Team, P4P = pay-for-performance, PM = performance metric, RCT = randomized controlled trial, VHA = Veterans Health Administration, VISN = Veterans Integrated Service Network

## Pay-for-Performance in Community Settings

A number of themes related to the design and implementation of P4P in community settings also emerged (see Table 13).

- Initially target areas in need of improvement such as documentation and coordination (eg, – receipt of records from community providers). Overwhelmingly, KIs felt that given known challenges related to receipt of documentation,^79,80^ data, and care coordination may be appropriate initial areas for P4P to target.
- Develop relationships with providers and health systems with records of strong performance on commonly used, well-validated, and well-established metrics. KIs stressed the importance of establishing relationships with local providers, and suggested a number of ways for selecting providers with track records of providing quality care.
- The likely small number of Veteran patients per community provider may pose a challenge, both in terms of accurately assessing quality and the potential for an incentive to influence behavior. Consider beginning with alternate approaches, such population-based incentives. Several KIs expressed concern aboutVA’s ability to influence provider behavior using P4P or to accurately estimate quality at the provider level, given that Veterans will compose a small percentage of any one provider’s patient population.
- Use strategies such as public reporting to complement P4P. Consistent with the findings from previous research,^3^ KIs stressed that P4P is just one part of a quality improvement strategy.
- Developing tools and resources to streamline the data-sharing and coordination necessary to inform a cross-system P4P program. Similar to findings from included studies,^77,79^ KIs noted on-going challenges in coordinating care with community providers, and suggested the development of tools to facilitate coordination.
- Consider how funding expanded care in the community might affect funding for Veterans receiving care in VHA settings. KIs voiced both concern for and uncertainty about how the Veterans Choice Program (VCP) may affect Veterans who continue to receive care in VHA.
- Consider how performance by community providers might impact measured performance for VHA providers. Several KIs noted that there may be Veterans who receive care both in the community and in VHA settings, and voiced concern for the potential impact on the achievement of VHA performance metrics, and possibly on the performance pay of VHA providers.
- Be vigilant for overtreatment and for differences in standards of care (eg, opioid prescriptions). KIs noted that one fundamental difference between care received in the VHA as compared to the community is that the VHA tends to be more conservative, and despite evidence of potential overtreatment in VHA settings,^21,22^ overtreatment is more common in community settings. In addition, consistent with included research,^77^ KIs voiced concern that community providers may be more prone to prescribing opioids than providers in the VHA.

Table 13 Evidence and Policy Implications - P4P in Community Settings

Implementation Framework Category | Study Evidence | Themes from Kl Interviews | Policy Implications
Program Design Features | One study^78^ examined program design features relevant to P4P in community settings, and found:; - A number of survey instruments examining cross-system access and coordination exist | A P4P program should be designed by first understanding the VHA’s larger (achievable) goals - and how expanding care for Veterans in the community through VCP better enables us to reach that goal. What to incentivize; - Consider incentivizing metrics such as timely access, documentation, and coordination; - Consider incentivizing aspects of care that differentiate the VHA from the care in the community; - Consider starting by looking at Veterans receiving care in the community as a population; How to choose quality providers/Who to incentivize; - Build relationship at the national and local levels; - Partner with established networks; - Contract only with board certified physicians; - Choose providers based on past performance on CMS metrics | - Initially target areas in need improvement such as documentation and coordination (eg, receipt of records from community providers); - Develop relationships with providers and health systems with records of strong performance on commonly used, well-validated, and well-established metrics
Implementation Factors | The 4 studies^76,77,79,80^ examining implementation factors found:; - Veterans, providers, and administrators reported VCP-related challenges such as fragmented care, poor communication and coordination, additional burden on VHA providers, and barriers to sharing medical records.; - There are differences between providers interested in VCP participation and those who are not, such as Veteran status and willingness to provide patient medical records. | Additional quality improvement strategies to consider in addition to P4P; - Public reporting; - Tools for community providers to streamline coordination of care; Challenges to P4P in community settings; - Limited number of Veteran patients per community provider; - VHA has a fragile relationship with community providers; - Mental health services in the community; Veterans have slightly different characteristics than the general population; thus, different health concerns and needs P4P in the community may impact Veterans receiving care in VHA settings and may influence providers and may influence the achievement of performance metrics for VHA providers | - The likely small number of Veteran patients per community provider may pose a challenge, both in terms of accurately assessing quality and the potential for an incentive to influence behavior.; - Use tools such as public reporting to complement P4P; - Developing tools and resources to streamline the data-sharing and coordination necessary to inform a cross-system P4P program; - Consider how funding expanded care in the community might affect funding for Veterans receiving care in VHA settings; - Consider how performance by community providers might impact measured performance for VHA providers
Provider Cognition, Affect, and Behavior | | P4P in the community may increase overtreatment and overuse | - Be vigilant for overtreatment and for differences in standards of care (eg, opioid prescriptions)

Abbreviations: P4P = pay-for-performance, VCP = Veterans Choice Program, VHA = Veterans Health Administration

## Limitations

Our report has a number of limitations. Given the limited research directly examining P4P in VHA settings and the heterogeneity in the way that P4P is implemented in the VHA, we were unable to form conclusions about the effectiveness of VHA performance pay on quality or health outcomes, and instead focus primarily on describing factors related to program design features, implementation factors, and unintended consequences. Similarly, research examining VCP is just starting to emerge, and as a result, our findings related to P4P in community settings are influenced heavily by findings from our key informant interviews. The breadth of topics and outcomes related to program design features, implementation factors, and unintended consequences made it difficult to restrict our criteria by study design. Thus, we included studies that utilized less-rigorous methodology, some of which had small samples. We interviewed 17 key informants to gain insight into factors important to the design and implementation of P4P in VHA and community settings. Although we aimed for a broad range of stakeholders, we recognize that a larger sample or different mix of KIs may have resulted in a different subset of themes identified. We also recognize that our aim to identify performance metrics that had been used in published research captures only a fraction of performance metrics used in P4P programs worldwide.

## Research Gaps/Future Research

Despite the fact that performance pay has been a part of VHA providers’ contracts for more than a decade, very little research has evaluated its effectiveness, and to our knowledge, no research has explored alternatives. The nature of the VHA as an integrated yet closed system provides opportunities to compare program design features and implementation factors, given the control a closed system provides.

Although Veterans seeking care in the community is not a new phenomenon, continued funding for the Veterans Choice Program necessitates the need for more comprehensive evaluation of the quality of care received by Veterans participating in VCP. Current research projects, programs, and initiatives funded largely by QUERI are evaluating metrics, quality, and P4P programs directly within the context of community care, but more research is needed to get a better sense of how expanded care in the community might impact Veterans receiving care in VHA settings – in particular vulnerable populations such as Veterans of color, low-income Veterans, and Veterans living in rural areas, for whom even community providers may be limited.

## Conclusions

The effectiveness of pay-for-performance in VHA settings has been largely understudied, but we highlight a number of key lessons learned from the implementation of programs that may help guide future P4P program improvements in VHA. In P4P programs targeting Veteran health in community settings, care should be taken to establish relationships with providers with track records of quality; consideration should be given to the impact of the small number of Veterans that will receive care in a given community setting per community provider; efforts should be made to develop resources and tools to better enable coordination of care, data-sharing, and record transfer; and special attention should be paid to mitigate the potential for overtreatment and ensure quality care for all Veterans.