# Results

## Literature Flow

We reviewed 1,031 titles and abstracts, and examined the full text of 74. We included 68 articles representing 62 studies; 7 articles informed more than one key question.^14–20^ In addition, we identified 23 VA-funded research projects, programs, and initiatives working on topics related to P4P (see Figure 2).

Figure 2 Literature Flow Chart

Note. Seven articles provided data for more than one key question. Abbreviations: ESP = Evidence-based Synthesis Program, KQ = key question, VCP = Veterans Choice Program.

## KEY QUESTION 1 What are the effects of pay-for-performance programs on the quality of care and health of Veterans?

Four articles^14–17^ from 3 studies^14,15,17^ provide data on the effects of P4P in VHA settings (see Table 2). Although the evidence shows promise, it is insufficient to draw firm conclusions about P4P’s effectiveness for the improvement of the quality of care or health of Veterans in VHA settings. One RCT found that the combination of audit and feedback and physician-directed incentives resulted in a small, short-term positive effect on blood pressure control, but incentives directed at the practice, and at both the physician and practice, were not associated with improved outcomes.^17^ 2 observational studies report evidence of positive effects on processes of care. However, it is possible that the findings of these studies may have been influenced by concomitant public reporting^14^ and denominator management (see KQ2 for more detail).^15^

Table 2 The Effects of Pay-for-Performance in VHA Settings: Summary of Findings

Study; - Study Design; - Sample Size; - Observation Period/Follow-up | Program Focus; - Incentive Target; - Incentive Amount; - Incentive Timing; - Other Intervention Factors | Detailed Process of Care Findings | Detailed Patient Health Findings | Findings Summary
Randomized Controlled Trial
Petersen et al, 2013^17^; - RCT; - 83 physicians and 42 practice team members (eg, nurses, pharmacists) from 12 sites; - 2007-2011 | Primary care: BP; - Physicians and/or Group; - $9.10 per measure, $4270 average group total, $1648 average provider; - 4-month performance period (up to 5 payments). Physicians with 2+ periods were included in the analysis.; - Education, audit and feedback | [underlined: Positive]: Proportion of patients achieving BP control [underlined: or] receiving an appropriate provider response to uncontrolled blood pressure (group difference 8.36 [95% CI, 2.4 to 13]; P = .005) Null: Proportion of patients receiving guideline-recommended antihypertensive medication 4.72 [95% CI, −1.44 to 10.92]; P = .09). | | A larger proportion of patients of providers receiving P4P achieved BP control [underlined: or] receive an appropriate response to high blood pressure. However, there was no difference in the use of guideline-recommended medications for high blood pressure.
Petersen et al, 2016^16^; - RCT, Petersen et al, 2013^17^ sub-study of AA/Black patients only; - 67 physicians; - 2007-2009 | | [underlined: Positive]: Proportion of patients achieving BP control [underlined: or] receiving an appropriate provider response to uncontrolled blood pressure (group difference 0.063 [95% CI, 0.008 to 0.117]; P = .03) [underlined: Positive]: Proportion of patients receiving an appropriate provider response to uncontrolled blood pressure (group difference 0.128 [95% CI, 0.003 to 0.253]; P = .05) [underlined: Null]: Proportion of patients receiving guideline-recommended antihypertensive medication (group difference 0.024 [95% CI, −0.028 to 0.075]; P = .37). | Null: Proportion of patients achieving BP control (group difference 0.021 [95% CI, −0.043 to 0.085]; P = 0.53). | P4P did not influence blood pressure control alone nor did the use of guideline-recommended medications for high blood pressure improve. However, patients of providers receiving P4P were more likely to achieve BP control [underlined: or] receive an appropriate response to high blood pressure.
Observational Studies
Benzer et al, 2014^14^; - Uncontrolled before/after; - 128 VA medical centers; - 2004-2010 | Acute care: acute coronary syndrome, heart failure, and pneumonia; - VISN and facility senior managers; - Bonuses (amount NR) NR; - Public Reporting | [underlined: Positive]: There were statistically significant improvements in 6 out of 7 measures related to acute coronary syndrome, heart failure and pneumonia (non-significant improvement for one heart failure measure). | | Performance improved on 6 of 7 quality of care measures.
Harris et al, 2016^15^; - Retrospective cohort; - 133 VA Medical Centers; - FY 2000 - 2009 | Substance use; - VISN Directors; - Included as part of the performance contract - up to 10% of annual salary; - Annual; - Positive findings of denominator management | [underlined: Positive]: Percentaqe of patients entering a specialty SUD treatment program who were retained for at least 90 days increased from 23.1% just prior to when the Continuity of Care (CoC) measure was added to VISN Directors’ performance contracts (FY 2002) to 48.3% (FY 2009), and increased at a rate of 0.7% per quarter (p<.001). | | The percentage of patients entering a specialty SUD treatment program who were retained for at least 90 days increased significantly after the measure was added to VISN Directors’ P4P contracts.

Abbreviations: AA = African American, BP = blood pressure, CoC = Coordination of Care, FY = fiscal year, NR = not reported, P4P = pay-for-performance, RCT = randomized controlled trial, SUD = substance use disorder, VA = Veterans Administration, VISN = Veterans Integrated Service Network

### Detailed findings

To date, only one RCT has examined P4P in a VHA setting.^17^ Petersen and colleagues compared audit and feedback plus incentives targeting 1) physicians, 2) practices, and 3) physicians and practices to audit and feedback alone (control) on guideline-recommended hypertension care. Across all subjects, physician-targeted, but not practice-level or combined incentives were significantly better than control in increasing the number of subjects either achieving blood pressure control or receiving an appropriate response to uncontrolled blood pressure. P4P, regardless of target, had no impact on the use of guideline-recommended medication.^17^ Among African American/Black subjects only, P4P did not influence blood pressure control alone nor did the use of guideline-recommended medication for uncontrolled blood pressure improve. However, patients of providers receiving P4P (all incentivized groups combined) were more likely to achieve BP control or receive an appropriate response to uncontrolled blood pressure.^16^

Two studies examined the effect of P4P using VHA administrative data.^14,15^ One study examined the effect of public reporting plus incentives targeting VISN- and facility-level senior managers on 7 inpatient guideline-concordant performance metrics for Veterans with acute coronary syndrome (ACS), heart failure, or pneumonia. Performance improved significantly for 6 of the 7 metrics, with improvements maintained through the two-to-four year incentivized period (varied by metric).^14^ The second study, which also targeted VISN Directors, examined the effect of P4P on the continuity of care for Veterans with specialty substance use disorders (SUDs). Performance increased non-significantly from 20.8% to 23.1% during the 12-quarter pre-implementation period at a rate of 0.2% per quarter, then significantly a rate of 0.7% per quarter after P4P was implemented, reaching 48.3% twenty-eight quarters later. Of note, findings also indicate that after P4P was implemented, the proportion of Veterans with SUDs who qualified for the performance metric denominator decreased significantly (see KQ2 for more detail).^15^

## KEY QUESTION 2 In Veteran populations, what are the potential unintended consequences of pay-for-performance in healthcare?

Thirteen articles from 11 studies (8 quantitative studies,^15–17,21–25^ 2 qualitative articles from the same study,^26,27^ and 3 others^19,20,28^) examined potential unintended consequences associated with pay-for-performance in VHA settings. In general, studies using administrative data and qualitative studies of VHA providers and leaders support the potential for overtreatment associated with performance metrics.^21,22,24,25^ However, the sole RCT of P4P specifically found no association between P4P for hypertension and hypotension.^17^ Furthermore, a qualitative sub-study of the same RCT found that despite no evidence of hypotension, a number of study participants reported concern for potential overtreatment.^28^ Other studies found evidence of denominator management associated with a VISN Director-aimed incentive,^15^ and no evidence of risk selection.^16,23^ Qualitative studies explored provider perceptions of both negative and positive unintended consequences associated with performance metrics.^26,27^ Figure 3 presents themes from KI interviews related to unintended consequences.

### Detailed Findings

#### Overtreatment

Of the 7 articles providing data on overtreatment, 2 examined P4P specifically,^17,28^ while the other 5 focused on the risk of overtreatment associated with performance metrics more generally (see Table 3).^21,22,24–26^ A RCT that compared audit and feedback plus P4P to audit and feedback alone for guideline-concordant hypertension treatment found no relationship between P4P groups and control in the development of hypotension.^17^ Furthermore, although there was no relationship between hypotension and P4P, a recently published qualitative sub-study of RCT participants found that participants were concerned that P4P would lead to overtreatment.^28^

Quantitative studies examining performance metrics more generally and using VHA administrative data^21,22,24,25^ found that the upper age cutoff for colorectal cancer screening was associated with possible overuse in 40% of Veterans aged 70–75 with a Charlson comorbidity index ‡4, that possible underuse in 16.5% of Veterans >75 with a Charlson comorbidity index of 0,^25^ and that 23% of screening colonoscopies between 2011–2013 met the definition for probable or possible overuse.^24^ In addition, among Veterans with diabetes, the facility rates for possible overtreatment associated with the clinical action metrics for hypertension and lipid management were 3–20%^22^ and 8.5–18.4%^21^ respectively, with higher rates of overtreatment significantly associated with higher rates of meeting the thresholds for both metrics (p<.001).^21,22^

In a qualitative study of unintended consequences associated with performance metrics, 32 of 59 VHA primary care providers and facility leaders interviewed expressed concern that performance metrics may be inappropriate for some patients, and 17 voiced specific concerns about the overuse of medication or treatment.^26^

#### Findings from Key Informant Interviews

Consistent with the literature, key informants voiced concern for potential overtreatment, particularly in facilities with metric-driven, rather than quality of care-driven cultures, and more commonly with metrics that vary, such as blood pressure. They also felt that one way to potentially mitigate overtreatment might be to include metrics focusing on prevention (eg, lifestyle counseling) and de-intensification.

Table 3 Unintended Consequences - Overtreatment: Summary of Findings

Study; - Study Design; - Sample Size; - Observation Period/Follow-up | Program Focus; - Incentive Target; - Incentive Amount; - Incentive Timing | Comparison | Detailed Findings | Findings Summary
Beard et al, 2013^21^; - Retrospective Cohort; - 964,818; - July 2010 to June 2011 | Diabetes; - NA; - NA; - NA | Examined rates of potential overtreatment in patients with diabetes associated with the clinical action measure for lipid management (proportion of patients with diabetes but without documented ischemic heart disease who were on high-dose statins). | 13.7% of all diabetics (n = 131,722 were potentially overtreated. Excluding patients with cerebrovascular and peripheral vascular diseases reduced the rate of potential overtreatment to 11.5%. Facility rates varied from 8.5-18.4%. Facilities with higher rates of meeting the lipid threshold measure (LDL <100 mg/dL) had higher rates of potential overtreatment (p<0.001). | Facility potential overtreatment rates ranged from 8.5-18.4%. The predicted probability of potential overtreatment was higher in facilities with higher rates of meeting the lipid threshold measure.
Hysong et al, 2017^28^; - Mixed-Methods Petersen et al, 2013^17^ sub-study; - 65 physicians from 12 sites; - 2007-2011 | Primary care: BP; - Physicians and Group; - $9.10 per measure, $4270 average group total, $1648 average provider; - 4-month performance period (up to 5 payments) | Conducted 30-minute interviews with RCT participants to identify unintended consequences associated with financial incentives. Examined real/actual consequences vs voiced concerns. | Although the potential for overtreatment was voiced as a concern by participants, a chart audit found no evidence of overtreatment. | Although the potential for overtreatment was voiced as a concern by participants, a chart audit found no evidence of overtreatment.
Kerr et al, 2012^22^; - Retrospective cohort; - 977,282; - July 2009 to June 2010 | Diabetes; - NA; - NA; - NA | Examined rates of potential overtreatment in patients with diabetes associated with the clinical action measure for hypertension (proportion of patients with systolic blood pressure < 130 and diastolic blood pressure < 65 and receiving 3+ blood pressure medications or active intensification). | 8% of all diabetics (n=80,903) were potentially overtreated. Facility rates varied from 3-20% (p<.001). Facilities with higher rates of meeting the hypertension threshold measure (<140/90 mm Hg) had higher rates of potential overtreatment (p<0.001). | Facility potential overtreatment rates ranged from 3-20%, with facilities in the highest quartile of meeting the hypertension threshold measure were 3.7 times more likely to be in the highest quartile of potential overtreatment.
Petersen et al, 2013^17^; - RCT; - 55 Physicians; - 2007-2011 | Primary care: BP; - Physicians and Group; - $9.10 per measure, $4270 average group total, $1648 average provider; - 4-month performance period (up to 5 payments) | Compared P4P to control providers | There was no difference in rates of hypotension when comparing patients of P4P providers to controls (1.2% vs 1.4%; P=.18). | There was no evidence of overtreatment.
Powell et al, 2012^26^; - Qualitative; - 59 VHA primary care providers and facility leaders at 4 VHAs; - Feb-July 2009 | Primary Care; - NA; - NA; - NA | Conducted a semi-structured 60-90 min interview to identify unintended consequences associated with implementing a national performance measures into local primary care practices. | 32 of 59 VHA primary care providers and facility leaders interviewed expressed concern that performance measures may be inappropriate for some patients, and 17 voiced specific concerns about the overuse of medications or treatments. | Participants identified a number of potential negative unintended consequences, including overtreatment.
Saini et al, 2014^25^; - Retrospective cohort; - 399,067; - 2008-2010 | Colorectal Cancer; - NA; - NA; - NA | Examined whether the upper age cutoff of the colorectal cancer screening measure was associated with overuse of screening among patients aged 70-75 in poor health and underuse in those over age 75 in good health. | Of Veterans 70-75 with a Charlson comorbidity index ≥ 4 (indicating poor health and shortened life expectancy), 40% underwent screening. Of Veterans >75 with a Charlson comorbidity of 0, 16.5% underwent screening. A 75-year-old Veteran who was unhealthy was more likely to undergo screening than a health 76-year-old (unadjusted RR = 1.64, 95% Cl 91.36, 1.97]. | Colorectal cancer screening was possibly overused in 40% of unhealthy Veterans 70-75, and possibly underused in 16.5% of Veterans >75.
Saini et al, 2016^24^; - Cross-sectional; - 88,754; - FY 2011 - FY 2013 | Colorectal Cancer; - NA; - NA; - NA | Examined screening colonoscopy overuse. | 23% (n=20,530) met the definition for probable (17%) or possible (6%) overuse. Common reasons for overuse were that it was < 6 months after a negative FOBT (35%), < 9 years after a negative colonoscopy (31%), and age 40-49(17%). | 23% of screening colonoscopies between 2011-2011 met the definition for probable or possible overuse.

Abbreviations: BP = blood pressure, FOBT = fecal occult blood test, FY = fiscal year, LDL = low density lipoprotein, NA = not applicable, P4P = pay-for-performance, RCT = randomized controlled trial, VHA = Veterans Health Administration

#### Other Unintended Consequences

Three articles from 2 studies examined other potential unintended consequences specifically associated with P4P, and focused on denominator management,^15^ risk selection,^16^ and unintended consequences more generally (see Table 4).^28^ Findings indicate that although a VISN Director-aimed incentive to increase the retention of Veterans enrolled in a specialty substance use disorder treatment program resulted in a significant increase after implementation, the percentage of patients meeting criteria for the metric denominator decreased significantly just both before and after P4P, with a more rapid decrease after P4P, and that facilities with higher pre-P4P denominators had steeper post-P4P denominator declines.^15^ In contrast, a RCT^17^ sub-study comparing audit and feedback plus P4P (aimed at providers, practices, or both) to audit and feedback alone for guideline-concordant care for African American/Black Veterans with hypertension found no evidence of risk selection.^16^ A second (qualitative) sub-study from the same RCT^17^ found that although participants voiced concerns for a wide range of negative unintended consequences, a chart audit revealed that with the exception of more time spent on data collection/clinical reminders, actual consequences were positive in nature.^28^

Related to performance metrics more generally, a retrospective cohort study examined comorbidity-related risk selection,^23^ and 2 articles from a qualitative study focused on negative unintended consequences^26^ and ancillary benefits of performance metrics for both providers and patients.^27^ Findings suggested that contrary to the hypothesized disincentives, complex patients had higher odds of receiving appropriate follow-up, and there were no differences in patient-reported satisfaction by comorbidity.^23^

Qualitative studies found that participants felt performance metrics may lead to negative unintended consequences such as reduced focus on patient needs/concerns, unincentivized areas of care, and/or healthier patient populations (teaching to the test/attention shift),^19,20,26^ and that they may negatively affect team dynamics, particularly if metrics are incentivized.^26^ Participants also suggested that performance metrics may indirectly increase patient knowledge and motivation, may directly result in increased patient satisfaction and psychosocial benefits associated with increased patient-provider communication, and that providers may experience increased pride in individual and/or organizational performance and confidence that standards of care are aligned with evidence-based medicine.^27^

#### Findings from Key Informant Interviews

Consistent with findings in the literature, key informants were concerned about denominator management – and challenges related to the denominator in general, given the subjective nature and variability in some diagnoses and treatment recommendations. Other concerns included risk selection and health disparities, particularly for low-SES Veterans, the need mitigate the potential for teaching to the test/attention shift, by having a variety of actively monitored [underlined: valid] metrics covering different aspects of care, and gaming.

Gaming

The reason you have things like gaming the system isn’t because people don’t want to do the right thing, it’s because they can’t do the right thing. – Key Informant

They stressed the history of gaming, particularly within the context of P4P. In addition, they stressed the need for adequate resources with which to respond to and achieve incentivized metrics, and felt that any lack of adequate support is likely to increase the potential for gaming.

Finally, there was disagreement among KIs about the use of composite metrics to mitigate gaming. One KI felt that the lack of transparency makes composite metrics more difficult to game, while still targeting care processes. However, another KI felt that there isn’t enough research to inform how to weight composite metrics, and that in addition, the goal of P4P should be to improve performance on specific metrics, rather than to improve a provider’s average.

Table 4 Unintended Consequences - Other: Summary of Findings

Type of Unintended Consequence | Study; - Study Design; - Sample Size; - Observation Period/Follow-up | Program Focus; - Incentive Target; - Incentive Amount; - Incentive Timing | Comparison | Detailed Findings | Findings Summary
Ancillary Benefits | Powell et al, 2014^27^; - Qualitative; - 59 VHA primary care providers and facility leaders at 4 VHAs; - Feb-July2009 | Primary care; - NA; - NA; - NA | Conducted a semi-structured 60-90 min interview to identify ancillary benefits associated with implementing a national performance measures into local primary care practices. | Performance measures may lead to educational interventions resulting in increased patient knowledge and motivation. Other benefits may include increased patient satisfaction and psychosocial benefits associated with increased patient-provider communication. Providers may experience increased pride in individual and/or organizational performance and confidence that standards of care are aligned with evidence-based medicine. | Participants identified numerous potential indirect and direct ancillary benefits for patients and providers associated with the implementation of performance measures.
Attention Shift | Damschroder et al, 2014^20^; - Qualitative; - 62 leaders, clinicians, and staff from 4 VHA facilities; - 2012 | Diabetes; - NA; - NA; - NA | Described the perceived impact of implementation of diabetes performance measures on management actions and day-to-day clinical practice. | Participants describe a punitive mentality, with leaders focusing on metrics that aren’t met, shifting attention from patient needs. | Participants describe a range of unintended consequences related to implementation, including attention shift.
| Kansagara et al, 2014^19^; - Qualitative; - 241 CIinical and Administrative Staff from 15 VHA Primary Care CIinics; - December 2010 and February 2013 | Primary Care; - NA; - NA; - NA | Described primary care staff experiences with the use of performance metrics during the implementation of the VHA PACT model of care. | Primary care staff perceived that Prii performance metrics are time per consuming and represented an per opportunity cost, with more tim attention paid to metrics that other pos areas of care, and to the patient uni populations performance metrics car are targeting. | Primary care staff ceived responding to formance metrics as e-consuming and ssibly distracting from ncentivized areas of e and/or populations.
Denominator Management | Harris et al, 2016^15^; - Retrospective cohort; - 133 VA Medical Centers; - FY 2000 - 2009 | Substance use; - VISN Directors; - Included as part of the performance contract - up to 10% of annual salary; - Annual | Compared proportion of patients with SUD who qualified for the denominator of the CoC measure before and after it was added to VISN Directors’ performance contract. | The percentage of patients who met the CoC measure denominator criteria decreased by 0.1% from 23.6% in FY 2000 to 22.1% in FY 2002 (p<.001), just before the measure was added to VISN Directors performance contracts. By the end of observation period (FY 2009), the percentage of patients meeting criteria for the denominator had fallen to 15.9% (p<.001), and the rate of decrease was more rapid after the measure was implemented (p=.02). In addition, facilities with higher pre-implementation prevalence had steeper declines after implementation (p<.001). | The percentage of patients meeting criteria for the CoC measure denominator decreased significantly pre- and post-P4P with a more rapid decrease after P4P. Facilities with higher pre-P4P denominators had steeper post-P4P denominator declines.
Provider Behavior | Powell et al, 2012^26^; - Qualitative; - 59 VHA primary care providers and facility leaders at 4 VHAs; - Feb-July2009 | Primary care; - NA; - NA; - NA | Conducted a semi-structured 60-90 min interview to identify unintended consequences associated with implementing a national performance measures into local primary care practices. | Participants identified a number of potential negative unintended consequences, and felt that performance measures, particularly those linked to pay, may negatively affect team dynamics. | Participants identified a number of potential negative unintended consequences, including a negative impact on team dynamics.
Risk Selection | Petersen et al, 2016^16^; - RCT Petersen et al, 2013^17^ sub-study of AA/Black patients only; - 67 physicians; - 2007-2009 | Primary care: BP; - Physicians and/or Group; - $9.10 per measure,; - 4-month performance period (up to 5 payments) | Compared P4P to control providers | Null: Percentage of patients who switched providers (25.1% both groups; p = 0.98) Null: Percentage of patients no longer assigned to original provider (28.8% P4P vs 29.6 control; p = 0.61) Null: Number of patient visits (M = 9.1 [SD = 8.1] P4P vs M = 9.0[SD = 8.4] control; p = 0.77) | There was no evidence of risk selection.
Risk Selection
Risk Selection | Petersen et al, 2009^23^; - Retrospective cohort; - 141,609; - FY 2005 | Hypertension; - NA; - NA; - NA | Compared appropriate follow-up received by hypertensive patients and patient satisfaction among those with and without comorbid conditions. | Adjusted odds of receiving an appropriate follow-up were higher for those with both concordant and discordant comorbid conditions, as compared to those with none (Adj OR = 1.64, 95% CI [1.57, 1.73] and Adj OR = 1.91, 95% CI [1.80, 2.02] respectively). There was no difference in the patients’ responses of having received “very good” or “excellent” quality of care by comorbidity. | Complex patients had higher odds of receiving appropriate follow-up for diabetes. There were no differences in patient-reported satisfaction by comorbidity.
Multiple | Hysong et al, 2017^28^; - Mixed-Methods Petersen et al, 2013^17^ sub-study; - 65 physicians from 12 sites; - 2007-2011 | Primary care: BP; - Physicians and Group; - $9.10 per measure, $4270 average group total, $1648 average provider; - 4-month performance period (up to 5 payments) | Conducted 30-minute interviews with RCT participants to identify unintended consequences associated with financial incentives. Examined real/actual consequences vs voiced concerns. | Although participants voiced concerns for a wide range of negative unintended consequences including reduced morale, reduced clinical flexibility, pressure to treat incentivized conditions to the detriment of the patient, and attention shift, a chart audit revealed that with the exception of more time spent on data collection/clinical reminders, actual consequences were positive in nature (improved documentation, improved morale, learning and development, positive spillovers). | Many unintended consequences of financial incentives noted were either only concerns or attributable to ancillary quality-improvement initiatives. Actual unintended consequences included improved documentation of care without necessarily improving actual care, and positive unintended consequences.

Abbreviations: AA = African American, BP = blood pressure, CoC = Coordination of Care, FY = fiscal year, NA = not applicable, P4P = pay-for-performance, RCT = randomized controlled trial, SUD = substance use disorder, VA = Veterans Administration, VHA = Veterans Health Administration, VISN = Veterans Integrated Service Network

Figure 3 Key Informant Interviews: Themes – Unintended Consequences

Note. Abbreviations: P4P =pay-for-performance, PM = performance metric (PM), SES = socioeconomic status, VHA = Veterans Health Administration

## KEY QUESTION 3 What metrics have been commonly incentivized in the published literature examining P4P programs?

Across 39 studies, we identified 82 process of care or administrative metrics, and 10 patient metrics (ie, intermediate and health outcomes, and evaluations of care) that have been reported as incentivized in published research examining P4P programs. Nineteen P4P programs in 8 countries are represented (see Table 5).

Table 5 P4P Programs Represented

Program | Process of Care | Patient Outcome
Australia’s Practice Incentives Program^29^ | X
CMS Medicare Hospital Value-Based Purchasing^30^ | X | X
English National Chlamydia Screening Programme^31^ | X
French National Health Insurance^32^ | X
Massachusetts General Physicians Organization^33^ | X
Medicare Advantage Prescription Drug Quality Compensation Program, TX^34^ | X
Netherlands GP P4P^35–37^ | X | X
Ontario’s Diabetes Management Incentive^38^ | X
Ontario’s Family Health Network, Family Health Group, Comprehensive Care Model, and Family Health Organization^39^ | X
Partners HealthCare Inc., MA^40^ | X
Radiology P4P in a 751-bed, urban, tertiary care adult teaching hospital^41^ | X
Regional Health Care Evaluation Program, Lazio, Italy^42^ | X
Rochester Independent Practice Association (RIPA)^43^ | X
Taiwan’s Diabetes Mellitus P4P^44–46^ | X
Taiwan’s Obstetric P4P^47^ | | X
Taiwan’s Pay-for-Performance on Tuberculosis^48^ | | X
UK’s Premier Hospital Quality Incentive Demonstration^49^ | X
UK’s Quality and Outcomes Framework^50–63^ | X | X
Veterans Health Administration^14,17^ | X

### Processes of Care

Incentivized metrics most commonly targeted cardiovascular health and diabetes, followed by pulmonary conditions and primary care. Screenings were the most common type of incentivized metric, followed by interventions/procedures, and prescribing. Metrics classified as “other” were predominantly administrative in nature (eg, trainings and EHR use). Table 6 presents a list of identified metrics organized by type and clinical condition. Figure 4 illustrates the distribution of metric types overall, and by clinical condition.

### Patient Outcomes

Very few patient outcome metrics were reported in published P4P research. The most common were intermediate measures such as blood pressure, cholesterol, and hemoglobin A1c targets, particularly in the United States and in the United Kingdom. 2 P4P programs in Taiwan were distinct from the others – one incentivizing stage-specific tuberculosis identification and cure rates,^48^ and the other providing incentives for vaginal births (see Table 7).^47^

Figure 4 Incentivized Process of Care and Administrative Metrics Reported in Published Literature by Condition and Type

Note. “Other” includes incentives targeting all physicians, radiology, inpatient, surgery, hip fractures, and influenza.

Table 6 Process of Care and Administrative Metrics Incentivized in Published P4P Literature

| Cardiovascular Health | Diabetes | Mental Health | Neurology | Primary Care | Pulmonary | Women’s Health | Other
Screening
Alcohol consumption recorded^64^ | X | X | | X | | X
BMI recorded^29,38,53,54,59,61,64^ | X | X | | X | | X
BP recorded^29,35,38,50,52,53,59,62,64^ | X | X | | X | | X | | X
Cervical cancer screening^35,39^ | | | | X
Chlamydia screening^31^ | | | | | X | | X
Colorectal cancer screening^39^ | | | | X
Glucose recorded^35,44–46,54^ | X | X
HbA1C recorded^29,34,35,38,43–46,52,53,59,61^ | X | X
HDL recorded^29,44^ | | X
LDL recorded^34,43,44^ | X | X
Lipids recorded^38^ | | X
Lithium levels recorded^52,53^ | | | X
Microalbumin testing recorded^29,38,59,61^ | | X
Neuropathy screening recorded^29,35,38,43,59,61^ | | X
Oxygenation assessed^49^ | | | | | | X
Peripheral pulses recorded^61^ | | X
Retinal screening recorded^29,35,38,43,59,61^ | | X
Serum creatinine recorded^34,35,38,44–46,53,61^ | X | X | X
Smoking status recorded^29,35,52,53,55,58,59,61,64^ | X | X | | X | | X
Spirometry/reversibility testing^37,53^ | | | | | | X
Thyroid function test recorded^52^ | | | | | | | | X
Total cholesterol recorded^29,35,38,44,52–54,59,61,64^ | X | X | | X | | X
Triglycerides recorded^29,44^ | | X
Urine albumin creatinine ratio recorded^50^ | | | | | | | | X
Weight recorded^14,38^ | X | X
Interventions and Procedures
ACEI or ARB for left ventricular systolic dysfunction^49^ | X
Aspirin administered on hospital arrival^49^ | X | | | | | X
Blood cultures performed in ED before initial antibiotics received^30,49^ | | | | | | X
Cardiology involvement within 24 hours^14^ | X
Diagnostic catheterization^14^ | X
Discharge instructions provided^30,49^ | X
Fibrinolytic therapy within 30 min of hospital arrival^49^ | X | | | | | | | X
Hand hygiene before/after patient contact^33^
Initial program enrollment and check-up^44^ | | X
Left ventricular systolic function assessed^49^ | X
Primary PCI within 90 minutes of hospital arrival^30^ | X
Prophylactic antibiotic within one hour prior to surgical incision^30^ | | | | | | | | X
Prophylactic antibiotics discontinued within 24 hours after surgery end time^30^ | | | | | | | | X
Proportion of surgeries for hip fracture performed within 48 hours of admission^42^ | | | | | | | | X
Self-management education^29^ | | X | | | | X
Smoking cessation advice^35,40,49,53,55,57,58,61^ | X | X | | | | X | | X
Stage-based guideline-recommended breast cancer treatment^65^ | | | | | | | X
Surgery patients on a beta blocker prior to arrival that received a beta blocker during the perioperative period^30^ | | | | | | | | X
Surgery patients who received appropriate venous thromboembolism prophylaxis within 24 hours prior to surgery to 24 hours after surgery^30^ | | | | | | | | X
Surgery patients with recommended venous thromboembolism prophylaxis ordered^30^ | | | | | | | | X
Troponin returned within 60 minutes of order^14^ | X
Timely antibiotic^14^ | | | | | | | | X
Prescribing
Aspirin prescribed at discharge^49^ | X
Benzodiazepine prescription reduction^32^ | | | X
Beta blocker prescribed at discharge^49^ | X
Guideline concordant prescriptions^17,36,58^ | X | | | | X
Initial antibiotic selection in immunocompetent patients^49^ | | | | | | X
Medication review^29,49,53^ | | X | | X | | X
Prescribed LARCs^51^ | | | | | | | X
Prescribed specific drugs/classes^14,36,37,50,52,60–62^ | X | X | | | X | | | X
Prophylactic antibiotic selection^30^ | | | | | | | | X
Received appropriate initial antibiotic selection^49^ | | | | | | X
Statins prescribed^35,37^ | X | X
Vaccinations
Influenza^34,35,38,39,52,53,56,61^ | X | X | | X | X | X | | X
Pneumococcal^14,38^ | | X | | | | | | X
Toddler^39^ | | | | | X
Appointments
Follow-up appointments^29,37^ | | | | | | X
No annual review follow-up in 14 days (psychoses)^53^ | | | X
Administrative
1+ prescription note in EHR 80%^33^ | | | | | | | | X
1+ problem note in EHR 80%^33^ | | | | | | | | X
Access to patient portal 10%^33^ | | | | | | | | X
CKD diagnosis recorded in EHR^50^ | | | | | | | | X
Communication training^33^ | | | | | | | | X
EHR notes within _ days of outpatient visit^33^ | | | | | | | | X
EHR radiology order entry^33^ | | | | | | | | X
EHR training^33^ | | | | | | | | X
Electronic education for patients 50%^33^ | | | | | | | | X
Electronic prescriptions^33^ | | | | | | | | X
Joint Commission evaluation^33^ | | | | | | | | X
Joint Commission training^33^ | | | | | | | | X
Med allergies in EHR 80%^33^ | | | | | | | | X
Median signature time < 8 hours or 80% of reports signed within 16 hours^41^ | | | | | | | | X
Review Meaningful Use performance dashboard^33^ | | | | | | | | X
Smoking status in EHR 50%^33^ | | | | | | | | X
Vitals in EHR 50%^33^ | | | | | | | | X

Abbreviations: ACEI = angiotensin converting enzyme inhibitor, ARB = angiotensin II receptor blockers, CKD = Chronic Kidney Disease, ED = Emergency Department, EHR = Electronic Health Record, PCI = percutaneous coronary intervention

Table 7 Intermediate, Patient Experience, and Patient Health Outcome Metrics Incentivized in Published P4P Literature

| Cardiovascular Health | Diabetes | Mental Health | Neurology | Primary Care | Pulmonary | Women’s Health | Other
Intermediate Outcomes
Blood Pressure Control^17,35,50,53,54,59,61–63^ | X | X | | X | | | | X
Cholesterol Control^35,53,54,59,61,63^ | X | X
HbA1c Control^35,53,59,61,63^ | | X
Glucose Control^54^ | | X
Lithium in Therapeutic Range^53^ | | | X
Patient Experience^30,35^ | X | X | X | X | X | X | X | X
Patient Outcomes
Vaginal Delivery^47^ | | | | | | | X
No Exacerbation^35^ | | | | | | X
TB Identified in months 1-3^48^ | | | | | | X
TB Cured in months 4-12^48^ | | | | | | X
Cardiac surgery patients with controlled 6am postoperative serum glucose^30^ | | | | | | | | X

Abbreviations: HbAlc = hemoglobin Ale, TB = tuberculosis

## KEY QUESTION 4 In Veteran populations, what program features and implementation factors modify the effectiveness of pay-for-performance programs?

### Program Features and Implementation Factors of Pay-for-Performance in VHA Settings

Sixteen articles from 13 studies (10 quantitative studies,^14,17,24,66–72^ 2 sub-studies,^18,73^ and 4 qualitative studies^19,20,74,75^) provide data examining program design features or implementation factors of pay-for-performance programs in VHA settings. In general, studies examining program design features found physician-targeted incentives to be more effective than those targeting groups/practices,^17^ that the degree of agreement between EHR data and manual review varied by metric,^18,24^ that the relationship between access metrics and patient satisfaction varied by access metric^71^ and whether the patient was new or returning,^72^ and that the difficulty of achieving multi-tasked metrics was not directly related to the number of tasks involved.^67^ Studies examining implementation processes found no difference in the achievement of actively versus passively monitored metrics,^68^ provide mixed evidence related to the impact of the removal of incentives on performance,^14,17^ and suggest areas of improvement for implementing performance metrics at the local level.^19,20^ One study examined provider affective/cognitive responses found that not only did P4P have no impact on goal commitment, but that physicians may perceive an external locus of control for hypertension care.^73^ 2 studies examined audit and feedback, one finding that higher-performing facilities reported delivering more timely, individualized, and non-punitive feedback,^75^ with the second reporting that the delivery of audit and feedback after Patient Aligned Care Team (PACT) implementation remained largely unchanged.^74^ Themes from KI interviews are provided in Figure 5, and study details are provided in Tables 8 and 9.

#### Detailed Findings

##### Program Design Features

A RCT compared physician-targeted, practice-targeted, and a combination incentive to control, and found that patients of providers receiving physician-targeted, but not practice- or combination-targeted incentives were more likely to achieve blood pressure control or receive an appropriate response to uncontrolled blood pressure. The incentive target did not influence the receipt of guideline-recommended hypertensive medication.^17^

Studies examining features of performance metrics found that for Veterans with hypertension, the agreement between manual chart review and automatic processing electronic health record (AP-EHR) guideline-concordant metric data varied by metric, with lower percentages observed in the EHR,^18^ and that as compared to manual chart review, using an electronic metric, colonoscopies could be correctly identified with high specificity, but with low sensitivity to overuse.^24^ Studies also found that there was poor agreement between CMS’ all cause hospital-wide 30-day readmission metric and condition specific metrics,^70^ that Diagnostic Cost Groups (DCGs) were better predictors of mortality and long-term care hospitalization than Adjusted Clinical Groups (ACGs),^69^ and that the number of tasks alone was not significantly related to the difficulty of completing complex clinical performance metrics; rather, that the difficulty of each step must be considered.^67^ With regard to access and wait times, Veteran satisfaction varied widely by access measure (eg, telephone contact, face-to-face, primary versus specialty care),^71^ and the relationship between patient satisfaction and specific wait time metrics (eg, first next appointment, desired appointment date, etc) were different for new and returning patients.^72^ Finally, when examining the relationship between mental health metrics and patient satisfaction, program reach and intensity, as well as treatment continuity, but not access to psychological services, were positively related to both access and encounter patient satisfaction.^66^

##### Findings from Key Informant Interviews

Larger Incentives

We’re being encouraged to do a lot of things to meet a lot of different quality measures. Or to do the right thing or check off different boxes in the process of clinical care. Not all of those things are necessarily being incentivized. Unless you make that incentive more salient, it makes it hard to stand out among all of the other things that we’re being encouraged to do. For example, for diabetic patients we’re trying to get people below the performance measure for HbA1C to 9%, we’re trying to get blood pressure controlled, we’re trying to get the right people to be on statins, we’re trying to get people to be taking aspirins. Depending on the medical center, there are different combinations of those things being incentivized, but we’re just trying to do the right thing for the patient and making sure the patient gets the right care. – Key Informant

Key informants consistently felt that VHA incentives need to be larger to be meaningful to the provider. Clinician KIs understood the tradeoff between incentive size and frequency, and consistently felt that once-yearly incentives weren’t frequent enough to influence behavior.

A number of key informants also thought that that the VHA should explore incentivizing teams, and other front-line staff.

Key informants also felt that performance metrics should be clinically meaningful. Although some KIs felt that a combination of process and outcomes metrics should be incentivized, others were less enthusiastic about incentivizing outcome metrics, because of the lack of provider control.

Consider Incentivizing Teams/Front-line Staff

Can you imagine giving a scheduling clerk the opportunity to earn an incentive? That might go a long way. – Key Informant

In addition, some KIs felt that the VHA should consider incentivizing administrative functions directly related to advancing quality. A number of KIs spoke about the challenges of incentivizing metrics related to access – as well as potential alternatives, with one KI suggesting that the VHA consider incentivizing efficiencies. Key informants stressed the importance of the feasibility of metric achievability, and felt that unrealistic metrics may result in adverse effects on staff.

Feasibility of attaining a measure is crucial

Case and point, if you say we want same-day access. Well that sounds great, but what if at your local climate your providers are at max 120% capacity and they are completely mismatched with supply and demand? And then you put it on the report card that you didn’t achieve same-day access, which is completely unachievable. That’s going to kill their morale. – Key Informant

A number of KIs also felt that more emphasis should be placed on de-intensification, and also mentioned potential barriers such as provider-patient buy-in, and the perception that it is more difficult to stop than start something.

Finally, KIs were interested in exploring alternative methods of identifying and validating performance metrics (eg, Productivity Measurement and Enhancement System [ProMES]), as well as the impact of the complexity of each step required to achieve a metric, and a number of them stressed the importance of validity – that the metrics accurately measure what they are intended to measure – regardless of whether or not they are incentivized.

Measures must be Valid

You’re going to be in trouble if you’re using metrics that are invalid or cease to be valid. You’re going to be investing your management effort and your money in achieving things that you didn’t set out to achieve. – Key Informant

Table 8 VHA Program Design Features - Summary of Findings

Type of Program Design Feature | Study; - Study Design; - Sample Size; - Observation Period/Follow-up | Program Focus; - Incentive Target; - Incentive Amount; - Incentive Timing | Comparison | Detailed Findings | Findings Summary
Incentive: Target | Petersen et al, 2013^17^; - RCT; - 83 physicians and 42 practice team members (eg, nurses, pharmacists) from 12 sites; - 2007-2011 | Primary care: BP; - Physicians and Group; - $9.10 per measure, $4270 average group total, $1648 average provider; - 4-month performance period (up to 5 payments) | Compared: 1) audit and feedback only, 2) physician incentives + audit and feedback, 3) group incentives + audit and feedback, 4) physician and group + audit and feedback. | A larger proportion of patients in the physician group achieved BP control or received an appropriate provider response to uncontrolled blood pressure (group difference 8.36 [95% CI, 2.4 to 13]; p=.005). There were no differences between control and practice incentives (group difference 3.24 [95% CI, −1.48 to 8.92]; p=.26) or physician + practice incentives (group difference 5.08 [95% CI, −0.04 to 10.56]; p=.09) There was no difference in the proportion of patients receiving guideline-recommended antihypertensive medication by incentive target. | Patients of providers receiving physician-targeted, but not practice-targeted or physician + practice-targeted incentives were more likely to achieve BP control or receive an appropriate response to high blood pressure. Incentive target did not influence the receipt of guideline-recommended hypertensive medication.
Metrics: Complexity | Hysong et al, 2016^67^; - Cross-Sectional; - 133 VA Medical Centers, 8 primary care providers; - FY 2000-2008 | Primary Care; - NA; - NA; - NA | Examined the difficulty of achieving clinical performance metrics by examining the complexity of the component tasks using Functional Job Analysis. | Metrics varied in the component number of tasks. Number of tasks was not significantly related to measure difficulty. Measures of chronic care following AMI had significantly higher difficulty scores than diabetes and screening measures, but not immunizations (F[3, 186]=3.57, p=0.015). The number of steps and each step’s difficulty must be considered when designing potential interventions for improving quality in a given metric or care area. | Both the number of steps and degree of difficulty of each step in a clinical performance metrics must be considered. Functional job analysis may useful in assessing the difficulty of clinical performance measures and variations among metrics and achievement.
Metrics: Data Source | Urech et al, 2015^18^; - Cross-sectional, Petersen et al, 2013^17^ sub-study; - 52 physicians and 33 practice team members (eg, nurses, pharmacists) from 12 sites (2,840 patients); - April-July 2009 | - Physicians and Group; - $9.10 per measure, $4270 average group total, $1648 average provider; - 4-month performance period (up to 5 payments) | Examined the agreement between automatic processing electronic health record (AP-EHR) data to data collected via manual chart review, and the impact on performance pay. | Data obtained via manual chart review resulted in higher percentages across all 3 outcomes (proportion of patients achieving BP control [overall agreement = 0.96, kappa = 0.87], proportion receiving an appropriate provider response to uncontrolled blood pressure [agreement = 0.64; kappa = 0.28], and proportion of patients receiving guideline-recommended antihypertensive medication [agreement = 0.85; kappa = 0.51]). AP-EHR data would result in mean payments being 10% less for guideline-recommended medication, and 8.3% less for BP control and appropriate provider response. | Agreement between manual chart review and AP-EHR data varied by measure, with lower percentages observed in the EHR.
Metrics: Risk Adjustment | Petersen et al, 2005^69^; - Cross-sectional; - 3,069,168; - FY 2001 | General; - NA; - NA; - NA | Compared risk adjustment using DCGs and ACGs, both with and without age, as well as the combination of age + gender, using all cause mortality and long-term care hospitalization. | For both outcomes, DCG + age was the best predictor (c-statistic morality = 0.830, LTC hospitalization = 0.890), followed by DCG alone. ACG was the poorest predictor for mortality (c-statistic = 0.700), and age + gender alone was the poorest predictor of LTC hospitalization (c-statistic = 05.93). | DCGs were better predictors of both mortality and long-term care hospitalizations than ACGs.
Metrics: Type | Kansagara et al, 2014^19^; - Qualitative; - 241 CIinical and Administrative Staff from 15 VHA Primary Care CIinics; - December 2010 and February 2013 | Primary Care; - NA; - NA; - NA | Described primary care staff experiences with the use of performance metrics during the implementation of the VHA PACT model of care. | Primary care staff perceived that performance metrics led to delivery changes that were not always aligned with PACT principles, such as efficient care delivery, and were not well-adapted to team-based care. | Primary care staff perceived that performance metrics were not consistently aligned with PACT principles of care.
Metrics: Validation | Frakt et al, 2017^66^; - Cross-sectional; - 6,990; - FY 2013 | Mental Health; - NA; - NA; - NA | Examined the extent to which facility-level administrative data-based performance metrics (program reach, psychosocial service access, program intensity, and treatment continuity) predict individual-level access and encounter satisfaction. | Broad measures of program reach and intensity positively associated with both access and encounter patient satisfaction. No measure of access to psychosocial services and nearly all measures of continuity are positively associated with both kinds of satisfaction. | Program reach and intensity, and treatment continuity, but not access to psychological services were positively related to both access and encounter patient satisfaction.
Metrics: Validation | Prentice et al, 2014^72^; - Cross-sectional; - 221,540 FY 2010 | Access; - Administrative data/SHEP | Examined the relationship between self-reported new and returning patient satisfaction (self-reported timely appointment, access to treatment and specialists, VA rating and satisfaction) and 1) first next available appointment, 2) retrospective create date, 3) prospective create date, 4) retrospective completed desired date, 5) prospective scheduled desired date | Appointment and prospective and retrospective create date were significantly related to all 5 measures of patient satisfaction. For returning patients, only the prospective scheduled desired date was consistently significantly associated with all 5 measures of satisfaction. | The relationship between access and patient satisfaction differs in new and returning patients, with first next appointment and appointment create dates better measures for new patients, and the prospective scheduled desired date a better metric for returning patients.
Metrics: Validation | Prentice et al, 2016^71^; - Cross-sectional; - 20,000-218,677 FY 2010, 2012 | Access; - Administrative data/SHEP | Examined the relationship between access metrics and 5 self-reported measures of patient satisfaction (timely appointment, access to treatment and specialists, VA rating and satisfaction) - 1) primary care third next appointment, 2) specialty care third next appointment, 3) speed of telephone response, 4) telephone abandonment rate, 5) primary care telephone clinics. Compared to previously established relationships between new patient create date and consult wait time metrics and patient satisfaction. | Third next appointment metrics are less reliable indicators of patient satisfaction. Both speed of response and abandonment rate predict Veteran satisfaction, with more consistent results found for speed of response. Primary care telephone clinics were valid for general satisfaction (VA rating and satisfaction) but not access metrics. | Veteran satisfaction varies widely by type of access measure (telephone vs face to face, primary care, specialty care).
Metrics: Validation | Rosen et al, 2016^70^; - Retrospective cohort; - 154 VA Medical Centers; - FY 2007-2010 | 30-day readmission rates for patients with heart failure, AMI, and pneumonia; - CMS Penalties; - NR; - NR | Compared CMS’ hospital-wide all-cause readmission measure to condition-specific measures of readmission. | Agreement ranged from 73.1% (HF) to 79.6% (AMI). Weighted k values were low, ranging from 0.11 for comparisons between the HWR and HF measures, to 0.17 between the HWR and AMI measures. Among those hospitals classified as poor performers by the heart failure readmission measure, only 28.6% were similarly classified by the HWR measure. The HWR measure penalized only 60% of those hospitals that would have received penalties based on at least 1 of the condition-specific measures. | There was poor agreement between CMS’ all-cause hospital wide readmission measure and the condition-specific readmission measures.
Metrics: Validation | Saini et al, 2016^24^; - Cross-sectional; - 2915; - FY 2011-2013 | Colorectal Cancer; - NA; - NA; - NA | Examined colonoscopy overuse, and compared manual review to an electronic measure. | The electronic measure was highly specific and correctly identified 97% of appropriate colonoscopies. However, the measure had low sensitivity, and correctly identified only 20% as overuse. | Colonoscopies can be correctly identified with high specificity, but with low sensitivity to overuse using electronic data.

Abbreviations: ACG = Adjusted CIinical Groups, AMI = acute myocardial infarction, AP-EHR = automated processing electronic health record, BP = blood pressure, CMS = Centers for Medicare and Medicaid Services, DCG = Diagnostic Cost Group, EHR = electronic health record, FY = fiscal year, HF = heart failure, HWR = hospital wide readmission, LTC = long term care, NA = not applicable, NR = not reported, PACT = Patient Aligned Care Team, VA = Veterans Administration, VHA = Veterans Health Administration

##### Implementation Factors

Studies focusing on implementation factors examined passive versus active performance metric monitoring^68^ and incentive removal.^14,17^ A retrospective cohort study examined the effect of changes in metric status from support indicators (passively monitored) to performance measures (actively monitored, and possibly incentivized) and vice-versa, and found that not only was there no significant relationship between metric performance and monitoring status, but that quality was either maintained or continued to improve.^68^ Quality was similarly sustained for up to 3 years in an (uncontrolled) study that examined VISN and facility senior manager-incentivized acute care metrics before and after incentives were removed.^14^ Conversely, Petersen and colleagues’ P4P RCT found a significant reduction in performance on guideline-concordant hypertension metrics after a 12-month washout period.^17^

Petersen and colleagues’ RCT also included audit and feedback via a website to both incentivized and non-incentivized participants, with participants receiving audit and feedback alone serving as controls. They found that incentivized participants were significantly more likely to access their feedback reports.^17^

Qualitative studies reported frustration with the implementation of metrics at the local level, feeling that implementation was guided by a “top down” approach,^19^ that providers were being held accountable for gaps in performance that were beyond their control,^20^ that metric implementation and clinical reminders weren’t always aligned with the evidence and VHA priorities,^20^ and that performance metrics were not always aligned with PACT principles of care.^19^ 2 studies examined audit and feedback – one that found that as compared to facilities with poorer records of guideline adherence, high-performing facilities tended to deliver more timely, individualized, and non-punitive adherence feedback to providers.^75^ The second examined audit and feedback after PACT implementation and found that clinical performance was still considered the responsibility of the physician, and that processes remained largely unchanged.^74^ Related to incentives, physicians reported a lack of transparency in the calculation of their performance pay.^20^

##### Findings from Key Informant Interviews

Improving the implementation of P4P and of performance metrics more generally in the VHA was a common theme among KIs. Related to implementation of performance metrics generally, KIs felt that some of the performance metrics are “opaque,” and that the rollout of new metrics (as well as existing ones) has largely lacked adequate interpretation (including purpose and intent), support documentation, and technical assistance. In contrast, KIs believed that performance metric implementation should be considered within the context of existing performance metrics, should be risk-adjusted, and should be accompanied by the financial, human, and other resources necessary to achieve them – such as a menu of approaches to improve performance, technical assistance, feedback and implementation support, and opportunities to collaborate and share ideas with people from other facilities and VISN networks.

P4P should be framed positively, and is just one aspect of quality improvement

(A negative frame) “You’re not doing the right thing. I’ve got to dangle cash in front of you so that I get your attention and get you to start doing the right thing for patients.” An alternative frame is, “You’ve got a lot of quality metrics to meet and this is really hard and I know you’re doing the right thing, but there’s a few of them that we’re going to highlight. We really think that this is a tool that’s going to help you do better with your patients more often and that’s why we’re doing this. In addition to this little reward that we’re offering, we’re also going to do X, Y, and Z to help you.” – Key Informant

Implementation should be accompanied by support documentation

In other words, it’s not, “Here’s the measure. Here is how the numerator and the denominator are defined. Here’s your goal.” Maybe there is some description of it, but packaging it with resources for responding and how to respond to the measure. I know that possible and actionable responses will vary from site to site… On a national level, it’s not going to be easy to generate that list, but it’s something to consider including in a package along with the performance measure that helps decrease the cognitive load for front line clinicians to have an idea of where to start. – Key Informant

There was strong consensus across KIs that P4P be implemented within the context of a larger quality improvement program. KIs felt that other important components were frequent and constructive audit and feedback, and public reporting – and that public reporting of P4P metrics in particular provides additional incentives both at the provider (to improve performance) and the administrative levels (to select valid, attainable, and evidence-based metrics). KIs also stressed that performance pay be framed positively, and they discussed the importance of creating a culture of learning, performance improvement, and quality.

Transparent, bottom-up, goal-aligned, and achievable

[An important factor is] transparency about the process and the criteria that are chosen. I think that also there should be some abilities for the line staff to help choose, shape, and mold the criteria being used. I think that would be the best thing. Say, “Here’s the a-la-cart menu. I’m going to propose we choose several of the following because we as a facility aren’t doing as well as other places.” Then we have people talk about that. You want the criteria to align with big VA goals that the Secretary and other leaders set. You have to align them with goals that you think are locally achievable based on the current climate at your facility. – Key Informant

Key informants also stressed that to succeed, providers must be given a “pathway to success,” which would and should differ by facility. This pathway might require additional resources, such as structural or technical improvements, and it may determine who should be incentivized. KIs also suggested coordinating national-level priorities with context-driven local needs by implementing the type of metrics that would indicate whether the local infrastructure is able to meet national-level goals.

KIs felt that VHA performance metrics have often been implemented from the top down, and that going forward, facility leadership should consider a bottom-up approach. They felt that providers and other staff should be included in decisions about which metrics to incentivize, or that at the very least P4P should be implemented in a manner through which people perceive organizational and procedural justice – that the process and outcomes are “fair.”

Related to the VHA’s current P4P program, there was strong consensus that more transparency is needed. Regardless of VISN or division, KIs who were providers could not identify the performance metrics linked to their pay. Finally, a number of KIs raised issues related to the reliability of the incentive – with numerous KIs stating that the budgetary allocation for performance pay has been unpredictable, resulting in uncertainty about whether incentives would be paid even if metrics were achieved.

Providers don’t know what their pay is linked to

For me, when I get money is random. Because of that I try to do a good job in general, but there’s not necessarily a strong tie between that money and my performance. If those dots were more connected it would maybe make my behavior different. – Key Informant

P4P should be reliable

Another thing that happens with my incentive is that you’re supposed to be eligible for some X% of your salary below some limit for incentives. My local VA has complete discretion over that depending on what their budget looks like, but when they pay me my incentive, they pay me some arbitrary amount of some total amount of what I could’ve gotten. It diffuses it even more. It makes it seem arbitrary, so why bother? – Key Informant

##### Provider Cognitive, Affective, and Behavioral Responses

Petersen and colleagues’ RCT’s audit and feedback process included an assessment of physician goal commitment to providing guideline-concordant hypertension care. They found no difference in goal commitment when comparing incentivized and non-incentivized physicians.^73^ Furthermore, commonly reported barriers were patient non-adherence and inconsistent follow-up, suggesting that providers may perceived an external locus of control in managing hypertension.

##### Findings from Key Informant Interviews

A number of KIs expressed the belief that physicians are intrinsically motivated, and that for most, the driving factor in achieving evidence-based performance metrics that make clinical sense is intrinsic motivation. Some felt that P4P’s extrinsic motivation to meet metrics that have less provider “buy-in” (eg, don’t make clinical sense to providers) may be interpreted as reducing their autonomy, and as contrary to their values. One KI offered an idea for an alternative that could potentially be both extrinsically and intrinsically motivating:

Intrinsic and Extrinsic Motivation

If I could be offered an incentive for meeting quality metrics that would generate a donation to a Veteran service organization or to Veteran families in need. Because VA is a really important safety net provider in many communities, could there be a way that instead of that $1,000 going to me, could it be going towards Veterans in need? I think that potentially could be more attractive to providers. If you think you need to do something extrinsic, that could be a nice extrinsic motivation, which at the same time link to the autonomous motivations of providers who choose to work in the VHA. That would really be kind of a win-win that way. There are not many incentives that offer a carrot but also speak to someone’s inner motivations. It just doesn’t happen very often because it’s usually one or the other. I think that if there could be creative incentives that could be tested in that way, I think that could be very exciting. – Key Informant

Table 9 VHA Implementation Factors and Provider Affective/Cognitive and Behavioral Response - Summary of Findings

Type of Implementation Factor or Provider Response | Study; - Study Design; - Sample Size; - Observation Period/Follow-up | Program Focus; - Incentive Target; - Incentive Amount; - Incentive Timing | Comparison | Detailed Findings | Findings Summary
Implementation Factors
Audit and Feedback | Damschroder et al, 2014^20^; - Qualitative; - 62 leaders, clinicians, and staff from 4 VHA facilities; - 2012 | Diabetes; - NA; - NA; - NA | Described the perceived impact of implementation of diabetes performance measures on management actions and day-to-day clinical practice. | Providers were frustrated by feedback reports that were dissociated from a realistic capability to address performance gaps. | Participants describe a range of issues related to implementation, including frustration about responsibility for performance gaps that are outside of their control.
Audit and Feedback | Hysong et al, 2006^75^; - Mixed-methods; - 102 facility directors, managers, and outpatient personnel at 6 VAMCs; - 2001 | Ambulatory Care; - NA; - NA | Explored the differences between high- and low-performing facilities in the use of clinical audit data for feedback purposes. | High-performing facilities provided timely, individualized, non-punitive feedback to providers, with more variability and a higher reliance on standardized facility-level reports found in facilities that were low-performing. Actionable feedback emerged as the core category from the data, around which timeliness, individualization, non-punitiveness, and customizability can be hierarchically ordered. | Facilities with a successful record of guideline adherence tend to deliver more timely, individualized, and non-punitive feedback to providers about their adherence than facilities with a poor record of guideline adherence.
| Hysong et al, 2014^74^; - Qualitative; - 48 clinicians, department heads, and facility leadership from 16 VAMCs; - NR | Primary Care (PACT); - NA; - NA; - NA | Described participants’ experiences with audit and feedback in team-based primary care settings, with the goal of identifying differences in processes after PACT implementation. | Ownership of clinical performance still rested largely with the provider. A panel-management information tool emerged as the most prominent change to feedback dissemination. Existing tools were seen as most effective when monitored by the nurse members of the team. Facilities reported few, if any, appreciable changes to the assessment of clinical performance after PACT implementation. | Audit and feedback processes remained largely unchanged.
| Petersen et al, 2013^17^; - RCT; - 83 physicians and 42 practice team members (eg, nurses, pharmacists) from 12VAMCS; - 2007-2011 | Primary care: BP; - Physicians and Group; - $9.10 per measure, $4270 average group total, $1648 average provider; - 4-month performance period (up to 5 payments) | Compared P4P to control providers | A significantly larger percentage of providers receiving P4P accessed their feedback reports via website, (67% P4P vs 25%; p=.001) | A significantly larger percentage of providers receiving P4P accessed their feedback reports
Incentive: Implementation | Damschroder et al, 2014^20^; - Qualitative; - 62 leaders, clinicians, and staff from 4 VHA facilities; - 2012 | Diabetes; - NA; - NA; - NA | Described the perceived impact of implementation of diabetes performance metrics on management actions and day-to-day clinical practice. | Providers did not have a clear understanding of how their P4P was calculated. | Participants describe a range of issues related to implementation, including the lack of transparency about performance pay.
Incentive: Removal | Benzer et al, 2014^14^; - Uncontrolled before/after; - 128VAMCS; - 2004-2010 | Acute care: acute coronary syndrome, heart failure, and pneumonia; - VISN and facility senior managers; - Bonuses (amount NR); - NR | Compared before/after incentive removal (up to 3 years) | Up to 3 years after removal of the incentive, latent growth models showed that performance was sustained for all 7 metrics (related to acute coronary syndrome, heart failure, and pneumonia), with no significant positive or negative slope (however weight monitoring showed a significant positive slope in the year following removal, then a significant negative slope the following year, and a nonsignificant slope in year 3 following removal). | Performance on quality of care metrics were maintained up to 3 years after incentive removal.
Incentive: Removal | Petersen et al, 2013^17^; - RCT; - 55 Physicians; - 2007-2011 | Primary care: BP; - Physicians and Group; - $9.10 per measure, $4270 average group total, $1648 average provider; - 4-month performance period (up to 5 payments) | Compared P4P to control providers | There was a significant reduction in performance. | There was a significant reduction in performance.
Metric: Implementation | Damschroder et al, 2014^20^; - Qualitative; - 62 leaders, clinicians, and staff from 4 VHA facilities; - 2012 | Diabetes; - NA; - NA; - NA | Described the perceived impact of implementation of diabetes performance metrics on management actions and day-to-day clinical practice. | Local performance metrics/clinical reminder targets aren’t always consistent with the evidence, the intent of the metric, and organizational priorities, and metric documentation and specifications aren’t always followed. | Participants describe a range issues related to implementation, including metric implementation that is not consistent with evidence or organizational priorities.
Metric: Monitoring | Hysong et al, 2011^68^; - Retrospective cohort; - 133 VA Medical Centers; - 2000-2008 | Ambulatory care: screening, immunization, chronic care following AMI, diabetes, hypertension; - VISN and facility senior managers (actively monitored measures only); - Bonuses (amount NR); - NR | Compared performance on metrics related to changes from passive monitoring (support indicators) to active monitoring (performance targets) or vice versa. Actively monitored measures may be incentivized. | Performance on all metrics improved or remained stable over time regardless of whether they changed from actively assessed to passively monitored or vice versa. After risk-adjusting for organizational characteristics, no organizational characteristics effects were found. 2/6 measures that changed from passive to active had significantly increased slopes after the change (HbA1c levels < 9, and colorectal cancer screening), indicating significant improvement in performance. 4/11 that changed from active to passive exhibited significant differences in slope; 2 exhibited positive slopes before the change, followed by negative slopes (lipid profile every 2 yrs; MDD screening), and 2 exhibited the opposite pattern (diabetic foot inspections; and pedal pulses). Remaining measures exhibited no significant changes, indicating sustained performance after changing from performance measure to support indicator. | Performance on all metrics improved or remained stable over time regardless of whether they changed from actively assessed to passively monitored or vice versa.
Metric: Transparency | Kansagara et al, 2014^19^; - Qualitative; - 241 Clinical and Administrative Staff from 15 VHA Primary Care Clinics; - December 2010 and February 2013 | Primary Care; - NA; - NA; - NA | Described primary care staff experiences with the use of performance metrics during the implementation of the VHA PACT model of care. | Primary care staff perceived that performance metrics were imposed from the “top down,” with little communication, transparency, or training. | Primary care staff perceived performance measures as being implemented from the “top down.”
Provider Affective/Cognitive and Behavioral Response
Goal commitment | Hysong et al, 2012^73^; - Cross-sectional Petersen et al, 2013^17^ sub-study; - 83 physicians from 12 sites; - 2007-2011 | Primary care: BP; - Physicians and Group; - $9.10 per measure, $4270 average group total, $1648 average provider; - 4-month performance period (up to 5 payments) | Compared provider goal commitment as part of the audit and feedback process by arm: 1) audit and feedback only, 2) physician incentives + audit and feedback, 3) group incentives + audit and feedback, 4) physician and group + audit and feedback. | There were no differences between goal commitment when comparing providers receiving financial incentives vs audit and feedback alone. In addition, patient non-adherence and inconsistent follow-up were cited as barriers to care. | No differences in goal commitment were found across all study arms or over time. Physicians may perceive an external locus of control for hypertension care.

Abbreviations: BP = blood pressure, MDD = Major Depressive Disorder, NA = not applicable, NR = not reported, PACT = Patient Aligned Care Team, P4P = pay-for-performance, RCT = randomized controlled trial, VAMC = Veterans Affairs Medical Centers, VHA = Veterans Health Administration, VISN = Veterans Integrated Service Network

Figure 5 Key Informant Interviews: Themes – Program Features and Implementation Factors in VHA Settings

Note. Implementation Factors include implementation processes; outer setting; inner setting; and provider characteristics. Abbreviations: P4P = pay-for-performance, VHA = Veterans Health Administration

### Program Features and Implementation Factors of Pay-for-Performance in Community Settings

We identified 5 studies examining pay-for-performance or related implementation factors in Veteran populations in community settings.^76–80^ In general, studies found that a number of survey instruments examining cross-system access and coordination exist,^78^ and that Veterans, providers, and administrators expressed concern that the Veterans Choice Program (VCP) had resulted in fragmented care for patients, poor communication and coordination amongst providers, and that it placed an additional burden on VHA providers. Other concerns included barriers to sharing medical records,^77,79,80^ and differences between providers interested in VCP participation and those who are not (see Table 10).^76^

In key informant interviews, a number of themes related to the use of P4P in the community as part of the Veterans Choice Program arose. Common themes related to identifying the overall goal of the VCP and the role of P4P, the types of metrics the VHA might consider incentivizing, tools to assist with care coordination, and suggestions for ways to ensure quality – such as how to choose providers/who to incentivize. In addition, KIs voiced concern for a number of potential challenges to implementing P4P in community settings.

#### Detailed Findings

##### Program Design Features

One study examined metrics relevant to community care. To address the question of patient experience with access and care coordination across multiple settings, researchers identified 31 existing survey instruments representing 6 access and 5 care coordination domains relevant to cross-system care. Domains frequently assessed included follow-up coordination, primary care access, cross-setting coordination, and continuity. They also interviewed a small sample of Veterans about their experience with community care. In addition to domains included in the existing instruments, Veterans also raised issues related to 1) acceptability of distance to care site given a patient’s clinical situation, 2) burden on patients to access and coordinate care and billing, and 3) provider familiarity with Veteran culture and VHA processes.^78^

Differences between care in VHA and community settings

Internally, we have a fairly strong sense of values and effort, finding the things that are going to make the biggest difference and not going for things just to do them, but doing things because we know they are going to make a difference. Those are bigger factors than having a performance measure on, “what’s your blood pressure?” Those are factors where VA care differs more from outside care…I think in general, if I were leading this, my first thought would be, “what is the clinical care that we want to change? What kind of care in the community would we want for it to be more like VA?” You start with that clinically, then you think, “what are the things we might do to influence that?” – Key Informant

##### Findings from Key Informant Interviews

A number of KIs stressed the importance of linking P4P in the community to the VHA’s organizational and program goals – thus, the importance of considering what types of metrics to incentivize in the community based on the overarching goal of the VCP. Prioritizing increased access to healthcare for Veterans was clear to KIs. However, questions arose with regard to other important goals. Some suggested simply the receipt of quality care, while others felt strongly about coordination of care, cost effectiveness, and “conservative care” (eg, careful selection of surgical patients). Some KIs wondered whether a goal of the VCP is or should be, to extend the type of care offered by the VHA to Veterans seeking care in the community, and if so, one KI suggested using the known differences between the VHA and community care as a guide to metric selection.

In terms of potential metrics to incentivize in the community, a number of KIs suggested that, particularly in the early stages of a program, P4P may be a strategy to address current challenges in the receipt and quality of patient records and documentation from community providers. Also, common among KIs was the notion that timely access, and coordination of care may be a good starting point. A few KIs also suggested that incentivizing guideline-based metrics at the (pooled) population level by comparing Veterans receiving care in VHA settings to those receiving care in the community may broadly address the question of the overall quality of care received by Veterans using the VCP, with the understanding that population-based incentives are unlikely to motivate behavior at the provider level.

Another question on the minds of KIs was how to choose community providers in a way that ensures quality care for Veterans. KIs stressed the importance of building relationships both at the national and local levels – that VHA providers should be talking to community providers. They also suggested using established networks, contracting only with board-certified physicians, and using providers’ performance on already-established metrics, such as those reported publicly by the Centers for Medicare and Medicaid Services, (CMS) as a method of selection.

Consider incentivizing documentation

One of the problems with Choice is that the records that we get back from the other health care systems aren’t very detailed. They provide basic information about billing but not much about the clinical care that’s been provided… One aspect of P4P might be in regards to getting good records…For example, for diabetes you’d want them to provide the tests being provided, the dates they were provided, and the data values for those lab tests. – Key Informant

##### Implementation Factors

A cross-sectional study compared characteristics and attitudes of community-based primary care and mental health providers reporting interest or no interest in VCP participation during early implementation, and examined perceptions and experiences of the VCP among “early adopters”. They found that providers who were Veterans were more likely to be interested in VCP, and that there were significant differences between interested and non-interested providers, including the willingness to accept Medicare rates and the willingness to submit copies of medical records.^76^

A qualitative study of pharmacists responsible for filling VCP prescriptions found that common challenges related to 1) non-formulary prescriptions, 2) opioids, and 3) HCV treatment – including lack of knowledge of VHA formularies, poor coordination and patient management, differences in standard and quality of care, and additional VHA burden.^77^ Other qualitative studies examining experiences with community care found that patients, as well as VHA providers and administrators reported poor coordination and fragmented care, poor communication, and challenges related to the sharing of data/medical records.^79,80^

##### Findings from Key Informant Interviews

Key informants generated ideas for a number of quality improvement strategies to accompany P4P for community providers. They stressed the importance of transparency in P4P programs generally, and felt that the performance of community providers should be publicly reported. In addition, they voiced concern about coordination and quality of care, particularly given the lack of shared electronic health records, and suggested developing resources and tools to streamline the process for community providers. Suggestions included developing a system to allow community provider access to the same pop-up reminders available within the VHA, and providing access to VHA formularies – either through the development of a new mobile app, or the use of existing tools, such as Epocrates®.

Differences between care in VHA and community settings

Internally, we have a fairly strong sense of values and effort, finding the things that are going to make the biggest difference and not going for things just to do them, but doing things because we know they are going to make a difference. Those are bigger factors than having a performance measure on, “what’s your blood pressure?” Those are factors where VA care differs more from outside care…I think in general, if I were leading this, my first thought would be, “what is the clinical care that we want to change? What kind of care in the community would we want for it to be more like VA?” You start with that clinically, then you think, “what are the things we might do to influence that?” – Key Informant

Limited Veterans per provider

As the VA becomes more like an insurance company, we need to start thinking like an insurance company. – Key Informant

A number of KIs discussed differences between Veterans and the general population – largely noting lower socioeconomic status (SES), mental health, substance use, and rural residence. KIs felt it important to account for SES when implementing P4P, and expressed concern for access and the availability of quality care for Veterans living in rural areas.

Limited Veterans per provider

Veterans are one percent of their patient population. Providers in the community are often working with 10 different insurers at once or more and the VA will literally probably be their smallest for a lot of them. For us to then say, “this is how you should practice differently” is a lot to ask under any circumstance, especially considering how poor the roll out has gone already. – Key Informant

In general, most KIs voiced concern for challenges the VHA might face in implementing P4P in community settings. Most commonly, KIs worried that Veterans accessing care through the VCP would be dispersed widely; thus, comprising a small percentage of any provider’s patient population, and that the VCP would simply become one of – and for many providers the smallest of – insurers they are working with. This in turn may both reduce the likelihood of any potential impact of a VHA P4P program (unless the incentive is large enough to stand apart from the rest), particularly if incentivized metrics differ from other programs, and would likely result in providers with so few VCP patients that measured performance would vary widely, resulting in unreliable measures of quality. KIs reiterated the potential for incentives related to access or data, as well as population-based incentives, and suggested aligning incentivized metrics with larger P4P programs. Other KIs discussed the potential tradeoffs of utilizing narrow networks to increase the percentage of VCP patients per provider, and access to high-quality care, particularly for rural Veterans.

Fragile relationship

You have to make sure that if you put these carrots out for Choice performance pay and the implementation of that program has a lot of wrinkles in it and the providers can never achieve to the point where they pay that money and they drop the VA, well than we have less options for community care and that is a detriment to our patients. That would be my biggest concern. – Key Informant

KIs were also concerned about the challenge presented by the already fragile relationship the VHA may have established with some community providers, citing slow payment and providers refusing Veteran patients as a result. They cautioned that the VHA should proceed with care, pay providers in a timely fashion, and reiterated the need for P4P to be achievable, fearing that an increased number of providers opting out may result in even poorer access for Veterans.

Challenges related to mental health

The culture in community mental health is “Big walls that are impermeable.” They don’t let data out. Its 2017 and there are people that are still handwriting their therapy notes. And of course, why wouldn’t they be? It makes sense if you’ve worked in the field, but it would make sense to no other health care provider. There are very unique challenged on implementing CHOICE and being able to ensure that the health care provided is of high quality. – Key Informant

Mental health treatment was a concern for a number of KIs as well. They feared that sending Veterans to community providers for mental health services will reduce coordination and the quality of care received, particularly for those with combat-related PTSD, substance use disorders, and those who are experiencing homelessness. In addition, KIs were concerned that implementing and incentivizing metrics will present a barrier to entry because performance metrics are uncommon in community mental health settings, and in addition, obtaining treatment notes and other records from providers will be challenging.

Finally, KIs were concerned about the impact of VCP on current patients and VHA providers – that in time, resources may be diverted from Veterans receiving care in VHA settings, and that the VCP may influence the ability for VHA providers to maximize their own performance pay.

Community P4P may affect VHA P4P

In terms of VA providers and how Choice would influence their ability to achieve max performance pay. From a VA provider’s perspective, you have to be somewhat mindful of the fact that with our current implementation of Choice, we have several times where there is failure to launch either because something gets dropped in the HealthNet referral process or we don’t get the records. If more and more Choice is going to be used into the future and Choice is going to be used for things that end up being criteria for [VHA provider] P4P, then I think that facility leaders have to be mindful of putting people in situations where they can’t succeed. – Key Informant

#### Provider Cognitive, Affective, and Behavioral Responses

KIs voiced concern for unintended consequences resulting from P4P in community settings – particularly overtreatment and overuse. They felt that not only might community providers be subject to the same dynamics that result in potential overtreatment in VHA settings, but that overtreatment may be even more common in the community, and that the lack of integration and coordination with VCP might place Veterans at increased risk.

Potential overtreatment

Even while we’re building access for other patients, there are major overuse problems out in the private sector. I worry that we’re opening the floodgates here a bit. I’ve seen that with a number of my patients where they’ve just gotten a number of things they don’t need for a variety of reasons. The VA, because we are an integrated system, have been able to keep a pretty good explicit and implicit check. So, if I’m ordering a very (expensive) cat scan and I know someone can’t get it for a month anyways, I may just not order it because it’s just not worth waiting that long. These checks in the system for overuse in the VA, along with other hard stops that help prevent overuse, if we just send people out into the private sector I just worry that we’re going to fuel that problem. – Key Informant

Table 10 Community Program Design Features and Implementation Factors - Summary of Findings

Type of Program Design Feature or Implementation Factor | Study; - Study Design; - Sample Size; - Observation Period/Follow-up | Program Focus; - Description of Sample | Comparison | Detailed Findings | Findings Summary
Program Design Features
Metrics: Development | Quinn et al, 2017^78^; - Qualitative and literature search; - 10 Veterans from a single VMAC who had been offered Community Care; - NR | General; - 8 of 10 Veterans accessed community care through VCP. Two opted for care in a VHA setting. | Map of existing patient experience survey instruments relevant to access and coordination of care across care settings, and a pilot evaluation of patient experiences conducted to help inform VHA development of a patient experience survey for Veterans eligible for the VCP. | 31 existing survey instruments representing 6 access and 5 care coordination domains relevant to cross-system care were identified. Domains frequently assessed included follow-up coordination, primary care access, cross-setting coordination, and continuity. In addition, Veterans raised issues related to 1) acceptability of distance to care site given patient’s clinical situation, 2) burden on patients to access and coordinate care and billing, 3) provider familiarity with Veteran culture and VHA processes. | Existing survey instruments assess many aspects of patient experiences with access and care coordination in cross-system care. However, additional factors such as patient burden and Veteran culture and VHA processes should be considered.
Implementation Factors
Implementation Processes | Gellad et al, 2017^77^; - Qualitative; - 27VHA Pharmacists; - September 2015 to October 2015 | Pharmacy; - Pharmacists responsible for filling VCP prescriptions | Sought to understand the barriers and facilitators to safe and effective medication dispensing under VCP. | Three themes emerged: 1) non-formulary prescriptions from VCP providers places a burden on pharmacists to educate providers about the formulary, and may result in delayed care due to difficulty reaching VCP providers and lack of a streamlined process, 2) challenges related to opioid prescriptions (eg, communication/education with VCP providers, Veterans needing to hand-deliver prescriptions, differences in standards of care for opioid prescribing), 3) concerns for inconsistent HCV care, medication adherence, poor coordination and patient management. | Pharmacists filling VCP prescriptions described challenges related to 1) non-formulary prescriptions, 2) opioids, and 3) HCV treatment, including lack of knowledge of VHA formularies, poor coordination and patient management, differences in standard and quality of care, and additional burden.
Implementation Processes | Tsai et al, 2017^79^; - Qualitative; - 38 Veterans and 10 VHA Providers from 3 VAMCs; - October 2015 to May 2016 | HCV; - Patients and providers involved in the VCP’s First Choice Initiative | Evaluated the implementation of the VCP and Choice First for HCV treatment. | Themes included difficulties with the approval, coordination, and communication. Patients and Providers felt they didn’t have a choices or control over care, with additional burden placed on the VHA provider. Patients and providers reported fragmented care, and providers reported barriers to sharing medical records. Other themes included provider reservations about community providers, and reservations about community providers having the expertise to meet the needs of unique Veteran populations. | Veterans and VHA providers report challenges with Choice First for HCV, including fragmented care, barriers to sharing medical records, increased burden on VHA providers, and concerns about the unique needs of Veterans being met in the community.
Implementation Processes | Zuchowski et al, 2017^80^; - Qualitative; - 23 VHA Women’s Health providers, staff, and administrators at 15 VAMCs; - NR | Women’s Health Gynecologists, Women’s Health Medical Directors, and other staff responsible for coordinating care with the community from 5 facilities with 0 FTEs, 5 with part-time FTE, and 5 with >1 full-time FTEs | Examined challenges to women’s health VHA and community care coordination. | Key informants reported substantial challenges in coordinating women’s health care between VHA and community settings. KIs reported that care was fragmented, that there is a lack of provider role clarity and tracking, poor VHA/community provider communication, and that challenges with health record exchange (eg, not timely, incomplete) results in a significant barrier to coordination. KIs provide suggestions such as the establishment of roles such as a “care tracker,” a provider point of contact, a patient liaison, and a records administrator. | Women’s health providers, administrators, and staff report significant barriers to coordinating VHA and community care, such as fragmented care, poor communication, lack of role clarity, and challenges with medical record exchanges.
Provider Characteristics | Finley et al, 2017^76^; - Cross-sectional; - 553 Community and 115 VCP Authorized Providers in TX and VT; - Summer/Fall 2015 | Mental Health: PTSD; - Prescribing and psychotherapy providers. VHA authorized providers were enrolled in either VCP or PC3. | Compared characteristics and attitudes of community-based primary care and mental health providers reporting interest or no interest in VCP participation during early implementation; and to examine perceptions and experiences of the VCP among “early adopters.” | Interest in VCP participation was associated with factors including being a Veteran and receiving VA reimbursement. Community and VCP authorized samples reported not knowing enough about the VCP, being unwilling to deal with claims/billing, and feeling that the reimbursement rate was inadequate. Of note, there was a significant difference between those interested and not interested in VCP participation in willingness to both accept Medicare rates and submit copies of medical records for the VHA record -- and even among those interested in VCP less than 65% were willing to submit records. Among the 21 providers who were attempting to become a VCP provider, mean satisfaction with the process was 4.85/10. Mean satisfaction among the 12 current VCP providers was 6/10. | Provider interest in the VCP was associated with factors such as being a Veteran. Community and providers cite reasons for unwillingness to participate in VCP. Significant differences between interested and non-interested providers include willingness to accept Medicare rates and willingness to submit copies of medical records.

Abbreviations: HCV = Hepatitis C Virus, NR = Not Reported, PC3 = Patient-Centered Community Care, SHEP = Survey of Healthcare Experiences of Patients, TX = Texas, VCP = Veterans Choice Program, VHA = Veterans Health Administration, VT = Vermont

Figure 6 Key Informant Interviews: Themes – Program Design Features and Implementation Factors in Community Settings

Note. Implementation Factors include implementation processes; outer setting; inner setting; and provider characteristics. Abbreviations: CMS = Centers for Medicare and Medicaid Services; P4p = pay-for-performance; VCP = Veterans Choice Program; VHA = Veterans Health Administration.

## KEY QUESTION 5 What novel approaches and/or current or recently closed research projects funded by VA examine the effectiveness, implementation factors, or unintended consequences associated with pay-for-performance in Veteran populations?

We identified no novel approaches to P4P being tested in clinical VHA settings. However, we identified 23 current and recently closed (2016 – present) projects, initiatives, and programs funded by VA (see Table 11). To our knowledge, only the Partnered Evidence-Based Policy Resource Center (PEPReC) is currently engaged in work directly related to P4P. Along with the Office of Community Care, they are developing performance standards for P4P in community-based treatment for opioid use disorder, and in addition, are designing a randomized evaluation of the resulting pilot program. All identified Quality Enhancement Research Initiative (QUERI) activities and one additional project (SDR 17–157, Wagner, T) relate to community care.

Table 11 Ongoing and Recently Closed VA-funded Studies and Programs

Project Number | Title | Principal Investigator | Location | Funding End
HSR&D and QUERI (https://www.queri.research.va.gov/partnered_evaluation/policy.cfm) | Partnered Evidence-Based Policy Resource Center (PEPReC) | Frakt, A | Boston, MA | NR
QUERI (https://www.queri.research.va.gov/choice_act/PTSD.cfm) | Factors Affecting Choice Act Implementation and Quality for Veterans with PTSD | Finley, E | San Antonio, TX | NR
QUERI (https://www.queri.research.va.gov/programs/triple_aim.cfm) | Triple Aim QUERI Program | Ho, Michael | Denver, CO | NR
QUERI (https://www.queri.research.va.gov/choice_act/implementation.cfm) | A Mixed-Method, Multi-Site Evaluation of the Implementation of the Veterans Choice Act | Ho, Michael | Denver, CO Cleveland, OH Seattle, WA | NR
QUERI (https://www.queri.research.va.gov/choice_act/quality.cfm) | Ensuring Quality and Care Coordination in the Era of Veterans Choice | Kerr, E | Ann Arbor, Ml | NR
QUERI (https://www.queri.research.va.gov/choice_act/women_veterans.cfm) | Examining VACAA Implementation and Care Coordination for Women Veterans | Mattocks, K | Northampton, MA | NR
QUERI (https://www.queri.research.va.gov/partnered_evaluation/access.cfm) | Partnered Evaluation of the Clinic Management Training Program/Center for Access Policy Evaluation and Research (CAPER) | Prentice, J | Boston, MA | NR
QUERI (https://www.queri.research.va.gov/programs/pact.cfm) | The Care Coordination QUERI: Improving Patient-Centered Care Coordination for High Risk Veterans in PACT | Rubenstein, L | Los Angeles, CA | NR
QUERI (https://www.queri.research.va.gov/choice_act/satisfaction.cfm) | Differences in Satisfaction with Choice: Laying the Foundation for the Evaluation of the Choice Act | Zickmund, S | Pittsburgh, PA | NR
CRE 12-023 (https://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141701774) | SUD Treatment Staffing and Handbook Implementation: Impact on Patient Outcomes | Frakt, A | Boston, MA | 5/31/2016
PPO 14-372 (https://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141704484) | Measuring Quality of Palliative Care for Patients with End Stage Liver Disease | Walling, A | West Los Angeles, CA | 9/30/2016
IIR 15-438 (https://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141705745) | Improving the Measurement of VA Facility Performance to Foster a Learning Healthcare System | Petersen, L | Houston, TX | 8/31/2017
IIR 12-383 (https://www.hsrd.research.va.gov/hsrd/research/abstracts.cfm?Project_ID=2141703268) | Linking Clinician Interaction and Coordination to Clinical Performance in VA PACT | Hysong, S | Houston, TX | 9/30/2017
CRE 12-035 (https://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141701790) | Identifying and Delivering Point-of-care Information to Improve Care Coordination | Petersen, L | Houston, TX | 9/30/2017
PPO 16-100 (https://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141705662) | Can Electronic Data and Natural Language Processing Accurately Reproduce a Surgical Quality Measure? | Richman, J | Birmingham, AL | 1/31/2018
SDR 17-157 (https://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141705691) | Planning for a New Era in Veterans Health Care: Community Care, Information Exchange and Multi-system Use | Wagner, T | Palo Alto, CA | 9/30/2018
IIR 14-082 (https://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141704516) | Glycemic Control: Overtreatment, Hypoglycemia, Mortality and De-Intensification | Tseng, C-L | East Orange, NJ | 2/29/2019
IIR 15-131 (https://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141704592) | Identifying, Measuring, and Facilitating Opportunities for De-intensification of Medical Services | Kerr, E | Ann Arbor, Ml | 10/31/201 9
IIR 15-436 (https://www.hsrd.research.va.gov/hsrd/research/abstracts.cfm?Project_ID=2141705653) | Using Data Integration and Predictive Analytics to Improve Diagnosis-Based Performance Measures | Hoggatt, K | Sepulveda, CA | 12/31/201 9
IIR 15-292 (https://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141705646) | Risk-Adjusting Hospital Outcomes for Veteran’s Socioeconomic Status | Trivedi, A | Providence, Rl | 1/31/2020
IIR 14-345 (https://www.hsrd.research.va.gov/hsrd/research/abstracts.cfm?Project_ID=2141705650) | Incorporating Treatment Outcomes into Quality Measurement of Depression Care | Pfeiffer, P | Ann Arbor, Ml | 3/30/2020
IIR 15-432 (https://www.hsrd.research.va.gov/hsrd/research/abstracts.cfm?Project_ID=2141705650) | Developing Benefit-Based Performance Measurement for VHA | Sussman, J | Ann Arbor, Ml | 6/30/2020
IIR 15-438 (https://www.hsrd.research.va.gov/hsrd/research/abstracts.cfm?Project_ID=2141705745) | Improving the Measurement of VA Facility Performance to Foster a Learning Healthcare System | Petersen, L | Houston, TX | 8/31/2020

Abbreviations: PACT = Patient Aligned Care Team, SUD = Substance Use Disorders, VA = Veterans Administration, VHA = Veterans Health Administration

In the course of the project, we also learned of 2 relevant unpublished studies, examining 1) the impact of the difficulty of coordination, documentation, and accomplishment of performance metrics on clinical outcomes (Sylvia Hysong, PhD, phone call, May 19, 2017) and 2) whether the mental models individuals and organizations hold regarding audit and feedback serve to moderate its effectiveness (Sylvia Hysong, PhD, email, September 9, 2017), as well as a proposal for research to assess the feasibility, accuracy, and interpretability of template matching versus conventional regression approaches for comparing quality of care across the VHA’s diverse settings (Hallie Prescott, email communication, August 2, 2017).