# Methods

## Topic Development

The key questions guiding this report were developed in collaboration with Clinton Greenstone MD, Deputy Clinical Director of Community Integration, VHA Office of Community Care, and with experts in the field:

Key Question 1 What are the effects of pay-for-performance programs on the quality of care and health of Veterans?
Key Question 2 In Veteran populations, what are the potential unintended consequences of payfor-performance in healthcare?
Key Question 3 What metrics have been commonly incentivized in published literature examining P4P?
Key Question 4 In Veteran populations, what program features and implementation factors modify the effectiveness of pay-for-performance programs?
Key Question 5 What novel approaches and/or current or recently closed research projects funded by VA examine the effectiveness, implementation factors, or unintended consequences associated with pay-for-performance in Veteran populations?

## Search Strategy

We identified primary evidence examining P4P in Veteran populations and performance metrics reported in published literature from the studies identified in our prior review,^3^ from an update search and a targeted search of known VA P4P and quality improvement researchers (PubMed, PsycINFO©, and CINAHL© [January 2014 to March 2017] see Appendix A for search strategy), and from a search of the VHA’s website for unpublished studies. To identify current and recently closed studies funded by the VA Office of Research and Development (ORD), we searched the Health Services Research and Development (HSR&D) and Quality Enhancement Research Initiative (QUERI) websites. We used snowball sampling to identify additional studies and novel approaches currently being tested or implemented in the VHA, starting with members of our Technical Expert Panel (TEP; see Appendix B), VHA leadership, and Veterans Integrated Service Networks (VISN) Directors.

## Study Selection

We included direct pay-for-performance programs targeting healthcare providers at the individual, group, managerial, or institutional level in VHA and Veterans Choice Program (VCP) settings (see study selection criteria in Appendices C and D). We excluded studies examining patient-targeted financial incentives, as well as payment models other than direct pay-for-performance (eg, managed care, capitation, bundled payments, and accountable care organizations). To assess the effectiveness of pay-for-performance on utilization, quality of care, and patient health outcomes (KQ1), we included all randomized and non-randomized controlled trials (RCTs and NRCTs), and observational studies that either a) had a comparison group, b) had 3 or more time points and reported a trend (eg, interrupted time series), or c) included 10,000 or more participants (eg, cross-sectional and uncontrolled before-after studies). All quantitative and qualitative study designs were included for key questions 2, 3, 4, and 5. To inform questions 2, 4, and 5, in addition to studies specifically examining performance pay, we also included relevant studies examining processes/variables that occur both upstream (eg, performance measures) and downstream (eg, audit and feedback) of P4P.

Two independent reviewers independently assessed studies for inclusion, and all discordant results were resolved through consensus or consultation with a third reviewer.

## Key Informants

We interviewed 17 individuals with extensive P4P research or administrative experience who were familiar with the VHA health system (see Appendix B for a list of key informants). The purpose of the interviews was to better understand the program features and implementation factors that might contribute to successful P4P programs in both VHA settings and those targeting Veteran care in the community.

We used conventional content analysis to guide protocol development and the analytic process.^8^ We drafted a semi-structured interview that probed previously identified themes^3,4^ which also allowed new themes and concepts to emerge. In addition, we asked specifically about anticipated challenges in constructing a P4P program guiding community care for Veterans (see Appendix E). All interviews were conducted by phone, were co-lead by 2 investigators, and averaged 60 minutes. Interviews were recorded and transcribed verbatim.

## Data Abstraction

Data from each study was abstracted by one investigator and confirmed by a second. From each study, we abstracted data related to study design, sample size, observation period, program focus, the incentive (target, size, timing), comparison, implementation factors, unintended consequences, and findings. For key question 3, we abstracted incentivized metrics from identified studies and removed duplicates by program (eg, Quality and Outcomes Framework).

## Quality Assessment

Two investigators independently assessed study quality using the Cochrane Risk-of-Bias tool^9^ for RCTs and the Newcastle-Ottawa Scale^10,11^ for observational studies (see Appendix F). We did not assess the quality of qualitative studies.

## Data Synthesis and Analysis

To analyze key informant data, 4 members of the team individually read each interview transcript and identified emergent themes and categories, which were then discussed with the full group. Following discussion, the group came to consensus regarding specific themes and categories to analyze further. A member of the research team reviewed all interview transcripts and tagged all quotes linked with identified themes and categories with a keyword, or “code.” All quotes identified by the same code were then compared and contrasted, both across and within interviews, by 2 members of the research team. Through this process, key themes and findings were refined and elaborated.

We qualitatively synthesized the results of included studies and key informant interviews into an implementation framework developed in consultation with the Technical Expert Panel (TEP) for the 2015 ESP pay-for-performance review,^3^ which was based largely on the Consolidated Framework for Implementation Research (CFIR).^12^ The framework describes the relationship between the features of P4P programs, external factors, implementation factors, and provider cognitive/affective and behavioral responses – on processes of care and patient outcomes (see Figure 1). Table 2 describes each framework category. Due to heterogeneity among the studies, meta-analysis was not performed.

We separated incentivized metrics from published research into patient outcomes (ie, intermediate, health, and evaluations of care) and processes of care (including administrative metrics), and organized them broadly by clinical condition (ie, cardiovascular health, diabetes, neurology, mental health, pulmonary, women’s health, and other). We further categorized processes of care metrics by type (ie, administrative, appointments, interventions/procedures, prescribing, screening, and vaccinations).

We briefly describe identified novel P4P programs, and provide a list of identified VA-funded ongoing and recently closed research examining P4P and related implementation factors.

Figure 1 Conceptual Framework

Note. Implementation Factors include implementation processes; outer setting; inner setting; and provider characteristics.

Table 1 Description of Implementation Framework Categories

Framework Category | | Description
Program Design Features | | Properties of the intervention itself such as the type of performance metric used or the size of the financial incentive
Implementation Factors | Implementation Processes | Actions taken to implement the P4P program such as planning, stakeholder engagement, academic detailing, audit and feedback, and whether the incentive was targeted at the team or individual level.
Implementation Factors | Outer Setting | Refers to the broader health system context within which an intervention is implemented; the cultural and social norms at the state and federal level; and characteristics of the patient population.
Implementation Factors | Inner Setting | Refers to characteristics of the institution or organization itself.
Implementation Factors | Provider Characteristics | Refers to demographic characteristics (eg, age, gender, race/ethnicity), as well as other factors such as experience and specialization.
Provider Cognitive/Affective and Behavioral Responses | | Refers to provider beliefs and attitudes. Includes cognitive response constructs such as biases, professionalism, heuristics, identification with one’s organization. Also includes behavioral response constructs such as risk selection, gaming, systems improvement responses.
Process of Care and Short-term Patient Outcomes | | Includes process of care outcomes such as performance of recommended screening or disease monitoring, as well as patient outcomes such as achieving target disease management goals (eg, blood pressure, cholesterol levels) and health outcomes.

## Rating the Body of Evidence

We assessed the overall strength of evidence for the effectiveness of P4P and Veteran care (KQ1) using a method developed for the Agency for Healthcare Research and Quality’s (AHRQ) Evidence-based Practice Centers (EPCs).^13^ Ratings were based on the following criteria:

- High = Very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies, the findings are stable, and another study would not change the conclusions.
- Moderate = Moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies and the findings are likely to be stable, but some doubt remains.
- Low = Limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). Additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Insufficient = No evidence, unable to estimate an effect, or no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

We did not assess the strength of evidence for other questions addressed in this report, given the heterogeneity inherent in research examining unintended consequences and implementation.