# Introduction

In pay-for-performance (P4P) programs, a portion of payments to providers, administrators, or health systems is linked to achievement of specific access to care, process of care, or patient outcome benchmarks. This strategy has become widespread in the Veterans Health Administration (VHA) since it was codified by law over a decade ago.^1^ Centers for Medicare and Medicaid Services (CMS)’ Merit-Based Incentive Payment System (MIPS) under the Medicare Access and CHIP Reauthorization Act of 2015 (MACRA) similarly heralds the establishment of P4P as a foundational strategy for health reform in the community.^2^

Even though P4P makes intuitive sense as a strategy to increase health care value, the empiric data are far from clear. In 2015, we completed a systematic review and key informant (KI) interviews broadly examining the benefits and harms associated with P4P in healthcare. We found that, while P4P programs may be associated with improved processes of care in ambulatory settings over the short-term, there was no consistent evidence of an effect on health outcomes. Through both the literature and KI interviews, we identified a number of potential unintended consequences associated with P4P, such as attention shift, gaming, and exacerbation of health care disparities; however, there were very few empiric data to firmly establish if and how commonly these occur. Information from both key informant interviews and a handful of studies suggested that P4P’s balance of benefits and harms likely depends heavily on the nuances of program implementation.^3–5^

In 2016, there were 25.5 million Veteran appointments in the community.^6^ In coming years, more and more Veterans are expected to receive care paid for by the VHA but provided in the community. The Commission on Care recommended that these payments be based on contemporary P4P strategies that incentivize quality and appropriate utilization.^7^ In other words, the challenge is to integrate payment and care from the nation’s largest health care system to a broad and diverse patchwork of community providers and health systems in a transparent and clinically meaningful way for a unique population of patients.

The purpose of the current project is to summarize the literature examining the benefits and harms of P4P specifically for Veterans, and to gain insight from experts in both P4P and Veteran care about the potential opportunities and pitfalls of P4P integration across health systems.