# APPENDIX G Peer Review Disposition Table

Reviewer Number | Comment | Response
Are the objectives, scope, and methods for this review clearly described?
1, 2, 3, 7 | Yes | Thank you.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1 | No | Noted
2 | Yes - You cite some presentations that led at least partly to publications: Frakt, Austin B., Jodie Trafton, and Steven D. Pizer. “The association of mental health program characteristics and patient satisfaction.” The American journal of managed care 23.5 (2017): e129. Prentice, Julia C, Michael L. Davies, and Steven D. Pizer. “Which outpatient wait-time measures are related to patient satisfaction?.” American Journal of Medical Quality 29.3 (2014): 227-235. | Thank you. We have replaced the presentation Frakt et al, 2016 with the suggested Frakt et al, 2017 publication, and we have added Prentice et al, 2014.
3 | No | Noted
7 | Yes - Hysong SJ, SoRelle R, Broussard Smitham KK, and Petersen LA (in press). Reports of Unintended Consequences of Financial Incentives To Improve Management of Hypertension. PLoS One. Hysong SJ, Knox MK, Haidet P. Examining clinical performance feedback in patient-aligned care teams. Journal of general internal medicine. 2014 Jul 1;29(2):667-74. Hysong SJ, Broussard Smitham KK, SoRelle R, Knox MK, Amspoker AB, Hughes A, Haidet P. Mental Models of Audit and Feedback in Primary Care Settings. In preparation, (target journal, Implementation Science) | Thank you. The in press article was published prior to the finalization of our report; thus, it was formally added to our synthesis. We also added Hysong et al, 2014. As the manuscript examining mental models remains unpublished, we added a brief description of the purpose to our section that describes unpublished work.
Is there any indication of bias in our synthesis of the evidence?
1, 2, 3, 7 | No | Noted
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
1 | This is a clearly written sequel to 2 prior reviews of P4P conducted by this ESP Center. It frames the question in terms of how the findings might apply to the Veterans Choice Program. While it hardly presents earth-shattering conclusions, it represents the literature fairly and provides a timely refresh of published studies that one hopes will inform policymaking, if not immediately, hopefully sometime in the future. The questions that are unanswered are those that remain unstudied - how do health outcomes change? What is the impact on physician morale esp burnout? beyond anecdote and qualitative assessments, how prevalent and important are the unintended consequences? Hopefully some of these questions will be addressed in future HSR&D funded research. | Noted, thank you.
2 | The content of the report is well organized and presented, but the text needs thorough proofreading and editing for grammar and clarity with issues on almost every page. These typically do not detract seriously from the content, but combine to undermine the credibility of the report. | Noted. We have thoroughly proofread and edited the report.
2 | Regarding substance, there is some tension between the idea of targeting incentives to providers instead of to systems or clinics and using population-based metrics. We want to target providers to improve the chance they will respond to the incentive, but we want population-based metrics to improve precision and encourage a population-based approach to care. It seems to me that this tension should at least be acknowledged. | Thank you. We have added a statement clarifying that population-based methods are unlikely to motivate behavior at the provider level.
2 | The boxed quote on page 56 is potentially very confusing. Perhaps the key informant intended to say “I’m ordering a very expensive cat scan,” but s/he said “valuable,” which suggests undertreatment instead of overtreatment. | Thank you for pointing that out. We have deleted “valuable” and replaced it with “(expensive).”
3 | This is an excellent document that 1 think will be quite helpful to VA as they try to apply their strengths to community care, where may of those strengths will be less usable. While structured in 5 key questions, there were really 2 projects here. In the first, they essentially described the research on P4P in VHA historically. In the second, they interviewed VA researchers who could help inform how VHA should approach this going forward. | Noted, thank you.
3 | Both projects were well-performed and their results were clearly presented. For a long document and a slightly diffuse project, 1 thought the document itself was readable and the findings were clear. While there are a few research decisions that 1 might have made differently, it was clear what decisions they had made and why. | Noted, thank you.
3 | For the question about how P4P has worked in VHA in the past, the answer was that the research isn’t very clear, they’ve used a lot of different measures, and there have been some unintended consequences, particularly overuse. The research has shown particular reliability questions with a clear rise in metric gaming and “denominator management.” | Noted.
3 | For the question of how P4P can work in VCA and in the future, 1 thought the interviewees overall gave a fairly large number of potentially useful ideas. The most important of these is to essentially remember that P4P choices are intended as tools to help implement whatever is important to the organization. The major initial concerns about VCA are probably more about access, coordination with VA providers, and making sure community providers access the services VA truly excels at (like PTSD and rehab care), than more traditional measures like blood pressure control. Relatedly, P4P should always be seen as one tool in an integrated implementation system that would also include decision support, education, and audit and feedback, among others. | Noted.
3 | My biggest problems with the document are not really addressable at this stage. My major problem was that the review work really focused on P4P in VA. However, if the question is how to use P4P to improve VCA, this is not ideal. I’d be more curious how individual insurers with non-dominant market shares have attempted to use P4P in the wild west of the community than how the centralized, mission-driven VA providers have used it. The difficulties of P4P in VCA will resemble those of private insurers more than that of internal VA historical issues. | Thank you. Given time limitations (this project had a six-month timeline) and the system-level and cultural differences between the VHA and the private sector, we focused on the VHA as a system due. We agree that future research should examine the issue of insurers with small market shares.
7 | p. 45, lines 52-53. The goal commitment study referenced did find no difference in goal commitment between incentivized and non-incentive physicians. More importantly, though, they found goal commitment to be modest at best, suggesting there were stronger situational factors that were impacting both physician types. | Thank you. We have edited the statement to read, “One study examined a provider affective/cognitive response, and found that not only did P4P have no impact on goal commitment, but that physicians may perceive an external locus of control for hypertension care.” To the detailed findings in Table 9, we have added “In addition, patient non-adherence and inconsistent follow-up were cited as barriers to care.”
7 | Figure 3. The Hysong et al. (in press) study referenced in the previous question provides new findings that many of the commonly discussed unintended consequences reflect concerns, rather than actual instances of unintended consequences occurring. | Thank you. Figure 3 highlights key informant themes, so we did not add findings from the recently published study to the figure. However, we have added the study to the report and discuss its findings.
7 | P. 21, Lines 29-31. Another way to potentially mitigate overtreatment is to incentivize appropriate care rather than treatment. In other words, follow a patient over time and see whether the series of decisions made for that patient led to patient improvement (including choosing not to treat). It would be more labor intensive but would not only mitigate over treatment, it would likely have more face validity with the clinicians. | Thank you. We have added the following statement to the summary and discussion section on overtreatment: However, it is possible that overtreatment may be mitigated by incentivizing appropriate care, rather than treatment or targets, as demonstrated by the single included RCT.
7 | Table 2 (p. 18) line 43 - Peterson should be spelled “Petersen” | Thank you. Corrected.
7 | P. 15 - Rating the body of evidence; did the reviewers only include high evidence strength studies? If not, what was the criteria for including the others? Too late now, but perhaps a better approach would be to code specific characteristics of the evidence in order to better assess the strength of the evidence. This method is generally considered stronger than blanket ratings of strength. | Thank you. In addition to rating the strength of evidence for the question of effectiveness (KQ1), we did quality assess all studies using the Cochrane Risk of Bias tool for RCTs and the Newcastle Ottawa Scale for observational studies. Detailed ratings can be found in Appendix F. Given that much of the report was descriptive, other than in our methods section, we did not refer to the ratings in the body of the report.