# APPENDIX F Risk of Bias Assessment

## Risk of Bias of Randomized Controlled Trials

Trial | Random sequence generation | Allocation concealment | Blinding of participants and personnel | Blinding of outcome assessment | Incomplete outcome data | Selective reporting
Petersen et al, 2013,^17^ 2016^16^ | Low | Low | Low | Low | Unclear | Unclear

## Risk of Bias of Cohort Studies

Study | Representativeness of the exposed cohort | Selection of the non-exposed cohort | Ascertainment of exposure | Description of concurrent QI Initiatives | Demonstration that the outcome of interest was not present at the start of the study | Comparability of cohorts on the basis of the design or analysis | Assessment of outcome | Follow-up long enough for outcomes to occur | Adequacy of follow up cohorts
Beard et al, 2013^21^ | Yes | NA | Yes | No | Yes | Yes | Yes | Yes | Yes
Benzer et al, 2014^14^ | Yes | NA | Yes | Yes | NA | NA | Yes | Yes | Yes
Harris et al, 2015^15^ | Yes | NA | Yes | Yes | Yes | NA | Yes | Yes | NA
Hysong et al, 2011^68^ | Yes | NA | Yes | No | NA | NA | Yes | Yes | Yes
Kerr et al, 2012^22^ | Yes | NA | Yes | No | Yes | Yes | Yes | Yes | Yes
Petersen et al, 2009^23^ | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | NA
Prentice et al, 2014^72^ | Yes | Yes | Yes | No | Yes | Yes | No | Yes | NA
Rosen et al, 2016^70^ | Yes | NA | Yes | Yes | Yes | Yes | Yes | Yes | NA
Saini et al, 2014^25^ | Yes | NA | Yes | No | Yes | Yes | Yes | Yes | Yes

## Risk of Bias of Cross-sectional Studies

Study | Representativeness of the sample | Sample size | Non-respondents | Ascertainment of exposure/risk factor | The subjects in different outcome groups are comparable, based on the study design or analysis. Confounding factors are controlled. | Assessment of the outcome | Statistical test
Finley et al, 2017^76^ | Yes | No | No | Yes | Yes | Yes | Yes
Frakt et al, 2017^66^ | Yes | Yes | No | Yes | Yes | Yes | Yes
Hysong et al, 2012^73^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Hysong et al, 2016^67^ | Yes | Yes | NA | Yes | NA | Yes | Yes
Petersen et al, 2005^69^ | Yes | Yes | NA | Yes | Yes | Yes | Yes
Prentice et al, 2016^71^ | Yes | Yes | NA | Yes | Yes | Yes | Yes
Saini et al, 2016^24^ | Yes | Yes | NA | Yes | Yes | Yes | Yes
Urech et al, 2015^18^ | Yes | Yes | NA | Yes | Yes | Yes | Yes