# APPENDIX E Key Informant Interview Guide

## Portland Evidence-based Synthesis Program

Pay-for-Performance and Veteran Care: Effects, Implementation, and Unintended Consequences

Introduction

■ ESP
■ Project
■ Project Description

1. Given your experience, what factors do you think are most important for the VA to consider in implementing pay for performance programs?
  b Can you give an example of a situation where [the factor/s mentioned above] made a difference in the success/failure of implementing a P4P program within VA?
  c Do you think factors influencing implementation success of P4P in the CHOICE Program would be similar to, or different, from those you mentioned above? Why?

Next I want to talk more specifically about aspects of P4P programs that you believe are important.

## Measures

2 Are there types of measures that you believe the VA should prioritize?
  a. Can you give us an example of such a measure?
3 Are there types of measures you have found problematic/think might be problematic within a VA context?
  a. Can you provide an example?
4 How might measures differ when used in the context of P4P versus the CHOICE Program?

## Incentives

5 Can you tell us about different types of incentives that you think are important (eg, rewards vs penalties, type/nature, frequency/duration, certainty)?
6 Do you think incentives used in the context of the CHOICE Program should differ from those used within VA? Why or why not?

## Implementation factors

7 What other implementation factors should the VA consider as they set up partnerships with the community?
  Probe: Implementation processes:
  - measure monitoring/evaluation,
  - incentive removal,
  - stakeholder engagement
8 How should the VA engage stakeholders as they start setting up partnerships in the community?
  Probe:
  - Inner setting (Institutional)
  - Outer setting (economic, political, social contexts)
  - Providers
  - Cognitive/affective responses
    ○ beliefs, attitudes
    ○ cognitive response constructs such as biases, professionalism, heuristics, identification with one’s organization
    ○ behavioral response constructs such as risk selection, gaming, systems improvement responses

## Unintended Consequences

9 As the VA moves forward with implementing P4P in the community, how can they minimize negative unintended consequences?
  ■ Examples:
    ○ Risk selection
    ○ Deterioration of un-incentivized care
    ○ Impairment of intrinsic motivation/professionalism
    ○ Gaming
    ○ Teaching to the test and/or overtreatment
10 Theoretically, community care can be very costly – and with a fixed budget, do you think it could potentially affect health disparities in Veteran populations? If yes, how so? Are these 2 populations likely to be different? And is there anyone working on this?
  ■ Examples:
    ○ Low income
    ○ Racial/ethnic minorities
    ○ Rural/distance from VHA
    ○ Homeless
    ○ Mental health
    ○ Disabilities
    ○ Women
    ○ LGBT
11 Do you know of anyone in the VA who is piloting novel performance metrics, novel approaches to P4P, etc. If so, who? (And can you tell us about these metrics or approaches?)
12 Is there anyone else you think it would be important for us to talk to?
13 Attached to the original email was a list of studies we identified for inclusion. Are there any others you suggest?
14 Is there anything else that you think it is important that we know?