# APPENDIX D Study Selection Criteria – Inclusion/Exclusion Criteria

1. Population: Is the study population Veterans?
  - Yes.......................................................................................................Proceed to #2
  - No ............................................................................................... Code X1 for KQ1. STOP
2. Financial Incentives: Does the article report outcomes and report outcomes separately for groups with and without financial incentives at the provider, managerial, group, or institutional level.
  - Yes ............................................................................... Proceed to #3
  - No ...............Code X2 for KQ1. Add code B if retaining for background/discussion. STOP
3. KQ2: Does the article discuss or report implementation factors that modify the effectiveness of financial incentives?
  - Yes ...........................................................Code I for KQ2. Proceed to #4
  - No ............................................................Code X for KQ2. Proceed to #4
4. KQ3: Does the article report unintended consequences/health disparities related to financial incentives?
  - Yes ...........................................................Code I for KQ3. Proceed to #5
  - No ............................................................Code X for KQ3. Proceed to #5
5. Outcomes Does the article report utilization, quality of care (eg, intermediate, patient evaluations of care), or patient health outcomes (modeling studies are not included)?
  - Yes ............................................................................... Proceed to #6
  - No ...............Code X3 for KQ1. Add code B if retaining for background/discussion. STOP
6. Publication Type: Does the article present original study data, a systematic review, or meta-analysis? Narrative or non-systematic reviews, letters, editors, and commentaries are excluded.
  - Yes ............................................................................... Proceed to #7
  - No ...............Code X4 for KQ1. Add code B if retaining for background/discussion. STOP
7. Systematic Review: Is the article a systematic review or meta-analysis of primary studies?
  - Yes ...............................................................................Code SR for KQ1. STOP
  - No .........................................................................................Proceed to # 8
8. Case Studies/Case Series: Does the article present a case study, case series, or case report?
  - Yes ...........................................................................Code X5 for KQ1. STOP
  - No .........................................................................................Proceed to # 9
9. Comparator/Study design: Is the article a primary study that compares a financial incentive to another financial incentive model or no financial incentive/usual care, or does it report 3 or more time points (and trend data), or have more than 10,000 participants
  - Yes ......................................................................................................... STOP
  - No ...............Code X7 for KQ1. Add code B if retaining for background/discussion. STOP.