# APPENDIX C Study Selection Criteria – Picots

Key Questions | KQ1. What are the effects of pay-for-performance programs on the quality of care in veteran populations? | KQ2. In Veteran populations, what are the potential unintended consequences of pay-for-performance in healthcare? | KQ3. What metrics have been commonly incentivized in the published literature examining P4P? | KQ4. In Veteran populations, what program features and implementation factors modify the effectiveness of pay-for-performance programs? | KQ5. What novel approaches and/or current or recently closed research projects funded by the VA examine the effectiveness, implementation factors, or unintended consequences associated with pay-for-performance in Veteran populations?
Population | Healthcare providers at the individual, managerial (eg, VISN directors), group, and institutional levels. Veteran populations whose providers/health care systems are being incentivized based on performance metrics.
Interventions | Pay-for-performance programs targeting providers, managers, health care systems
Comparators | Other financial incentive models; other payment models (eg, fee for service, bundled payments)
Outcomes | Utilization of healthcare services Quality of healthcare services Intermediate outcomes/process of care metrics Patient evaluations of care Patient health outcomes
Timing | Long- or short-term
Study design | RCTs, NRCTs. Eligible observational studies: have a comparator, ≥3 time points and report a trend (eg, ITS), or n≥10,000 cross-sectional or uncontrolled before-after study | All quantitative and qualitative study designs.
Setting | VHA, CBOCs, or community sites serving Veteran populations | | VHA or healthcare systems similar to the VHA or the US | VHA, CBOCs, or community sites serving Veteran populations