# APPENDIX B Technical Expert Panel and Key Informants

## Technical Expert Panel Member and Key Informant

- Justin Benzer, PhD
  Research Health Scientist; Department of Veterans Affairs
  Associate Professor; University of Texas at Austin Dell Medical School
  Research Associate Professor; Public Health, Texas A&M University
- Laura A. Petersen, MD, MPH, FACP
  Associate Chief of Staff for Research; Michael E. DeBakey VA Medical Center
  Director; Center for Innovations In Quality, Effectiveness, and Safety (IQuESt)
  Professor of Medicine, Chief of Section of Health Services Research; Baylor College of Medicine
- Laura Damschroder, MS, MPH
  Investigator; Center for Clinical Management Research, VA Ann Arbor Healthcare System
- Rachel Werner, MD, PhD
  Core Investigator; VA Center for Health Equity Research and Promotion (CHERP)
  Professor of Medicine; Division of General Internal Medicine, University of Pennsylvania Perelman School of Medicine
  Director of Health Policy and Outcomes Research, Medicine; University of Pennsylvania Perelman School of Medicine
  Senior Fellow; Leonard Davis Institute of Health Economics, University of Pennsylvania Attending Physician; Philadelphia VA Medical Center

## Key Informants

- Alvaro Sanchez, MD
  Chief Medical Officer; VA Midwest Healthcare Network (VISN 23)
- Gary Young, JD, PhD
  Director; Northeastern University Center for Health Policy and Healthcare Research
  Professor of Strategic Management and Healthcare Systems; Northeastern University
- Hallie Prescott, MD, MSc
  Assistant Professor; Department of Internal Medicine, University of Michigan Medical School
- Ilse Wiechers, MD, MPP, MHS
  Assistant Professor of Psychiatry; Yale University School of Medicine
  Associate Director of the Northeast Program Evaluation Center; VA Office of Mental Health Operations (OMHO)
  National Program Director; Psychotropic Drug Safety Initiative
- Jeff Kullgren, MD, MS, MPH
  Research Scientist; VA Center for Clinical Management Research, VA Ann Arbor Healthcare System
  Assistant Professor; Department of Internal Medicine, University of Michigan Medical School and Institute for Healthcare Policy and Innovation
- Jeremy Sussman, MD, MS
  Research Scientist; Center for Clinical Management Research, VA Ann Arbor Health System
  Assistant Professor; Department of Internal Medicine, University of Michigan Medical School
- James F. Burgess, Jr., PhD
  Senior Investigator; HSR&D’s Center for Healthcare Organization and Implementation Research (CHOIR)
  Director of the Health Economics Program; Boston University
- Joan E. McInerney, MD, MBA, MA, FACEP
  Network Director; VISN 2
- Praveen Mehta, MD
  Chief Medical Officer; VISN 12
- Scott Pawlikowski, MD
  Primary Care Lead Physician; VA Great Lakes Healthcare System, VISN 12
- Steven D. Pizer, PhD
  Director of Health Care Financing and Economics; VA Boston Healthcare System
  Associate Professor; Department of Pharmacy Practice and Department of Economics, Northeastern University
- Sylvia J. Hysong, PhD
  Investigator and Ph.D. Fellowship Program Director; Health Policy, Quality & Informatics
  Program, Center for Innovations in Quality, Effectiveness and Safety, Michael E. DeBakey VA Medical Center
  Associate Professor; Department of Medicine, Section of Health Services Research, Baylor College of Medicine
  Adjunct Assistant Professor; University of Houston
- Tim Hofer, MD, MSc
  Professor; Division of General Medicine, University of Michigan
  Associate Director for Analytic and Information Resources; VA Center for Practice Management and Outcomes Research