# APPENDIX A Search Strategies

## Main Search: March 14, 2017

(((((((((“Minority Health”[Mesh]) OR (“Healthcare Disparities”[Mesh] OR “Health Status Disparities”[Mesh])) OR “Racism”[Mesh]) OR “Sexism”[Mesh]) OR “Homophobia”[Mesh]) OR “Observer Variation”[Mesh])) OR ((((((unintended[Title/Abstract] OR unanticipated[Title/Abstract] OR unforeseen[Title/Abstract] OR Unexpected[Title/Abstract] OR unplanned[Title/Abstract] OR undesired[Title/Abstract] OR unconscious [Title/Abstract])) OR exception reporting[Title/Abstract]) OR preferential reporting[Title/Abstract]) OR bias[Title/Abstract]) OR (gaming[Title/Abstract] OR spillover[Title/Abstract] OR “risk selection” [Title/Abstract] OR unincentivised[Title/Abstract] OR nonincentivised[Title/Abstract])))) AND (((“Physician Incentive Plans”[Mesh]) OR “Reimbursement, Incentive”[Mesh]) OR “economics”[Subheading]) AND VA filter: ((“Veterans Health”[Mesh])) OR (((VA OR Veteran OR VAMC OR Veterans)) OR (“Veterans”[Mesh] OR “United States Department of Veterans Affairs” [Mesh] OR “Hospitals, Veterans”[Mesh]))
Limited to Publication Date after 1/1/2014
PubMed | N = 107
CINAHL (after deduplication with PubMed search) | N = 34
PsycINFO (after deduplication with PubMed and CINAHL) | N = 116

## Author Search: March 28, 2017

(((((Petersen L[Author]) OR Kerr E[Author]) OR Hofer T[Author]) OR Benzer J[Author]) OR Werner R[Author]) OR Volpp K[Author]
PubMed | N = 618