# SUMMARY AND DISCUSSION

In this chapter, we describe the limitations of our review and meta-analysis and then present our conclusions. We also discuss the implications of our findings for future research.

## Limitations

### PUBLICATION BIAS

Our literature search procedures were extensive and included canvassing experts from academia regarding studies we may have missed. It was not possible to conduct formal tests for publication bias, but even with such tests it is not possible to exclude the possibility that such bias exists. Therefore, readers are cautioned about this possibility.

### STUDY QUALITY

An important limitation common to systematic reviews is the quality of the original studies. Recent attempts to define elements of study design and execution that are related to bias have shown that in many cases, such efforts are not reproducible and do not distinguish study results based on bias. Therefore, the current approach is to avoid rejecting studies or using quality criteria to adjust the meta-analysis results. We did use the QUADAS criteria and those suggested by Hayden and colleagues as a descriptive measure of quality. As there is a lack of empirical evidence regarding study characteristics and their relationship to bias, we did not attempt to use other criteria. Other aspects of the design and execution of a trial may be related to bias, but we do not yet have good measures of these elements. Because of the small number of studies found, it was not possible to do sensitivity analyses based on study quality.

### HETEROGENEITY

In our meta-analysis, it was not possible to calculate a test of heterogeneity. Clearly, the populations being assessed were different, and there were also important differences in how some key variables were measured, which diagnostic tests were used, and which reference standard for classifying osteoporosis was used, among others. This heterogeneity further limits our ability to draw strong conclusions.

### APPLICABILITY OF FINDINGS

Green & Glasgow94 provide a framework for evaluating the relevance, generalization, and applicability of research. Their framework includes assessing the participation rate, the intended target population, the representativeness of the setting, the representativeness of the individuals, and evaluating information about implementation and assessment of outcomes. As these data are rarely reported in the studies we reviewed, conclusions about applicability are necessarily weak.

## Conclusions

With the above limitations in mind, we reached the conclusions displayed below.

### KEY QUESTION #1: What are the prevalence of and risk factors for osteopenia, osteoporosis and osteoporotic fractures among men in general and among male Veterans specifically?

#### Prevalence

- There are no VA specific data on prevalence of osteopenia and osteoporosis in men.
- Applying NHANES III estimates of prevalence to veteran-specific enrollee data we estimate the prevalence of osteoporosis in male veterans of 200,000 – 400,000; and of osteopenia in male veterans of 2–3 million.

#### Risk Factors

- We found a high quality meta analysis, and a limited number of articles specific to the risk factors alcohol use, diabetes mellitus type II and spinal cord injury. Based on these findings, our review suggests the following.
- Strong predictors of an increased risk of osteoporosis in men include age, low body weight, physical inactivity, and weight loss. (GRADE quality of evidence = High; further research is very unlikely to change our confidence on the estimate of effect.)
- Certain health conditions and medications also are strong or moderate predictors of an increased risk of osteoporosis in men. The most relevant to VA are prolonged systemic corticosteroid therapy and androgen deprivation (in the context of prostate cancer treatment). (GRADE quality of evidence = Moderate; further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.)
- Alcohol use is probably associated with an increase in osteoporotic fractures, but is not clearly associated with an increase in osteoporosis as measured by BMD. (GRADE quality of evidence: Fractures = Moderate; further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate; BMD = Very Low; any estimate of effect is very uncertain.)
- There is no evidence that diabetes mellitus type II is a significant risk factor for osteoporosis in men. (GRADE quality of evidence: Low; further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.)
- Spinal cord injury is associated with an increase risk of osteoporosis and possibly osteoporotic fractures. (GRADE quality of evidence: BMD= Moderate; further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate; BMD = Very Low; any estimate of effect is very uncertain; Fractures= Low; further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.)

### KEY QUESTION #2: Are there any validated tools to screen for osteoporosis in men?

- The evidence for screening tools for men is much more limited than for women. We were only able to synthesize evidence on two screening tools: calcaneal ultrasound and the Osteoporosis Screening Tool (OST).
- There is no evidence to suggest that calcaneal ultrasound performs differently in men than in women. (GRADE quality of evidence = Moderate; further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.)
- The OST appears to have comparable (and possibly better) test characteristics than calcaneal ultrasound in diagnosing DXA-determined osteoporosis. (GRADE quality of evidence = Low; further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.)
- Although calcaneal ultrasound does not appear to be a particularly good test at diagnosing DXA-determined osteoporosis, it is a strong, independent predictor of fractures in men. (GRADE quality of evidence = Moderate; further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.)
- Limited data are available on other screening modalities and there is a large gap in our understanding of osteoporosis screening tests in men.

### KEY QUESTION #3: What values of BMD determined by DXA (and by different DXA techniques) have been used to diagnose osteopenia and osteoporosis; and what is the evidence regarding the relationship between differing definitions and the development of osteoporotic fractures?

- The values of BMD determined by DXA that have been used are based on standard deviations (T-score) away from a reference standard, either young female or young male.
- Whether to use a young female or a young male reference range in order to identify men as “at risk” for osteoporotic fractures is an area of controversy that is not possible to resolve with existing data.
- Until more definitive evidence is available, we believe it is most logically consistent for VA to identify men who might benefit from treatment for osteoporosis by adhering to the same conditions as were used in the RCTs of osteoporosis treatment; namely, the young male reference standard. (GRADE quality of evidence = Low; further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.)