# RESULTS

## Literature Flow

In total, we examined 580 titles. The electronic literature search identified 508 articles. An additional 68 articles were identified through reference mining. Content experts identified 4 more articles.

Of the titles identified through our electronic literature search, 186 were rejected as not relevant to the project. This left 394 from all sources. Four articles were excluded at abstract review. One title could not be located after contacting many sources.

Initial screening of the articles resulted in 176 articles that addressed risk factors for osteoporosis. We found 27 articles that addressed diagnostic tools for osteoporosis, and 31 articles about differing DXA levels and risk of fracture. (Figure 1)

Figure 1 Male OP Literature Flow

## Key Question #1: What are the prevalence of and risk factors for osteopenia, osteoporosis and osteoporotic fractures among men in general and among male Veterans specifically?

### PREVALENCE

We identified 20 articles that compared osteoporosis and men in Veteran populations.10,19,27–44 All of the articles dealt with patients selected from specific populations such as nursing homes, pulmonary clinic, rheumatology clinic, etc.; or, were convenience samples. Thus there are no population-based data on the prevalence of osteoporosis in male veterans.

A study assessing the prevalence of osteoporosis using a T-score of >2.5 standard deviations below the young male reference standard, based on data from the National Health and Nutrition Examination Survey III (NHANES III), estimated that the prevalence in men was 3%–6% for osteoporosis, and 28%–27% for osteopenia.11 Applying these estimates of prevalence to VA-specific enrollee data yields estimates of 200,000 to 400,000 male veterans with osteoporosis and 2 to 3 million male veterans with osteopenia.

### RISK FACTORS

We identified a high quality systematic review and meta-analysis seeking to identify factors to help select subjects for bone densitometry assessments.45 This review searched multiple computerized databases up to 1997 and identified 94 cohort studies, 72 case control studies, and 1 randomized clinical trial. Most studies were performed in subjects older than age 50 and used American or European populations. Where feasible, the authors used fixed-effects methods to provide meta-analytic pooled estimates of risk. They classified risk factors into the following groups:

- “High risk”: an associated Relative Risk (RR) or Odds Ratio (OR) of greater than or equal to 2.
- “Moderate risk”: risk vales of between 1 and 2.
- “No risk”: risk values close to or equal to the null value, or even a protective effect.
- “Unclassifiable”: the data are insufficient or contradictory to reach a conclusion.

The authors performed separate analyses for men and for women, found no important differences, and presented their results for both sexes combined. Table 1 presents the main results of their study.

Table 1 Classification of risk factors for fracture related to bone mass loss(taken from reference 45)

High risk (15%)^*^ | Moderate risk (18%)^*^ | No risk (8%)^*^ | Unclassifiable (59%)^*^
Aging (> 70–80 years) Low body weight^a^ Weight loss^b^ Physical inactivity^c^ Corticosteroids Anticonvulsants Primary hyperparathyroidism^†^ Diabetes mellitus type I^†^ Anorexia nervosa^†^ Gastrectomy^†^ Pernicious anemia^†^ Prior osteoporotic fracture | Gender (female) Smoking (active) Low sunlight exposure (low or none) Family history of osteoporotic fracture^d^ Surgical menopause^e^ Early menopause (<45 years)^f^ Short fertile period (<30 years)^g^ Late menarche (>15 years)^h^ No lactation Low calcium intake (<500–850 mg/day) i Hyperparathyroidism (N/S) Hyperthyroidism Diabetes mellitus (type II or N/S) Rheumatoid arthritis | Consumption of caffeine Consumption of tea Menopause^j^ Nulliparity Consumption of fluoridated Water Thiazide diuretics | Alcohol intake Long-term immobilization Type of menopause^k^ Menopausal discomfort Prior practice of athletics High number of children Old age at parity Other reproductive factors^l^ Male hypogonadism Other hormonal factors in men Mineral nutrient intake Dietary deficiency of vitamin D Dietary deficiency of vitamin C High-protein diet Deficient nutritional intake indicators Other dietary habits Prostaglandin inhibitors^m^ Thyroid hormone replacement therapy Non-thiazide diuretics Tamoxifen Anti-ulcer agents Metabolism and gastrointestinal absorption disorders^n^ Other thyroid disorders^o^ Respiratory diseases^p^ Neoplasm^q^ Paget’s disease Peptic ulcer Thalassemia Lithiasis

N/S, not specified.

* Percentage of total risk factors identified.

† There is little available scientific evidence for this risk factor, its quality also being moderate. However, the available studies show a consistent and significant increase in fracture risk.

a BMI (body mass index) lower than 20–25 kg/m2 or weight under about 40 kg.

b Greater than 10% (compared with the usual young or adult weight, or weight loss in recent years).

c No physical activities are performed regularly (walking, climbing stairs, carrying weights, housework, gardening, or other).

d Hip fracture in first-degree relatives was the most frequently studied risk factor.

e Due to bilateral oophorectomy.

f Before 45 years.

g Duration less than 30 years.

h From 15 years.

i Less than 500–850 mg/day (patient’s age and gender should be assessed) or low/no consumption of dairy products such as milk (<1 glass/day) or cheese.

j Menopause, due to nonspecified cause or by oophorectomy (unspecified uni- or bilateral).

k Surgical vs natural.

l Includes those related to menstrual cycle, miscarriages, hysterectomy and tubal ligation.

m Includes aspirin and other nonsteroidal anti-inflammatories.

n Includes hepatic cirrhosis, chronic renal failure, regional enteritis, gastrointestinal resection.

o Includes goiter, adenoma and unspecified glandular disorders.

p Includes asthma, chronic bronchitis and emphysema.

q Includes endometrial carcinoma, breast carcinoma and any type of neoplasm.

We also identified a recent review (2005) that assessed risk factors for fractures.46 While not a systematic review, the paper is authored by leaders in the World Health Organization osteoporosis community, and presents summaries of data originally presented in research articles (primarily by the co-authors). Included in this paper is a table summarizing their assessment of risk factors for osteoporotic fractures, with an additional notation indicating those factors that confer extra risk over and above that determined by BMD. That table is reproduced here as Table 2.

Table 2 Risks for osteoporotic fractures (taken from reference 46)

Female gender | Premature menopause
Age^a^ | Primary or secondary amenorrhoea
| Primary and secondary hypogonadism in men
Asian or Caucasian race | Previous fragility fracture^a^
Low BMD | Glucocorticoid therapy^a^
High bone turnover^a^ | Family history of hip fracture^a^
Poor visual acuity^a^ | Low body weight^a^
Neuromuscular disorders^a^ | Cigarette smoking^a^
| Excessive alcohol consumption^a^
| Prolonged immobilisation
| Low dietary calcium intake
| Vitamin D deficiency

a These characteristics capture aspects of fracture risk over and above that provided by BMD

Of the 176 articles that we identified which assessed risk factors for osteoporosis in men, we identified those that concentrated on factors for which prior reviews demonstrated an uncertain evidence base and factors that might have specific importance to the VA population.

These data were discussed with the Evidence Synthesis Project Steering Committee. After reviewing the risk factors about which there was still some uncertainty, they identified diabetes mellitus type II or NOS, spinal cord injury and alcohol use as factors most relevant to the VA and directed us to pursue a more detailed evaluation of articles relevant to these factors.

We therefore selected the 45 articles that measured one of these risk factors and assessed them with a brief screening form (Appendix A). Table 3 presents the results. There were 38 articles that assessed alcohol use, 15 that assessed diabetes mellitus and 4 that assessed spinal cord injury. Eight studies were cohorts, 9 were case control studies, and 28 were cross sectional in design. Almost all studies adjusted for, or in some way accounted for confounding by age, body weight, cigarette smoking, and physical activity, but adjustments for other potential risk factors were rare and variable.

Table 3 Descriptive Data about Risk Factor Articles

Risk Factor Assessed: | Number of Articles
Alcohol | 38
Diabetes Type II or NOS | 15 *includes 12 articles that also assessed alcohol
Spinal Cord Injury | 4
Study Design:
Cohort | 8
Case-Control | 9
Cross Sectional | 28
Outcomes Assessed:
cDXA | 28
Site:
Spine | 17
Femur | 23
Other | 9
Osteoporotic Fracture | 19
Assessed by:
X-ray | 11
Medical Record Review | 8
Administrative data | 4
Diary | 4
Other Bone Measurements | 8
Ultrasound | 2
Other | 8
Covariates Adjusted for: | Percent of Articles
Age | 82%
Low body weight | 84%
Weight loss | 9%
Physical inactivity/prolonged immobilization. | 71%
Corticosteroid use | 36%
Anticonvulsant use | 16%
Hyperparathyroidism | 9%
Diabetes Type I | 0%
Gastrectomy | 13%
Hypogonadism, primary or secondary | 16%
Poor visual acuity | 2%
Previous osteoporotic fracture | 29%
Cigarette smoking | 89%
Vitamin D deficiency | 16%
Low dietary calcium intake | 60%
Family history of osteoporosis | 31%
Hyperthyroidism | 20%
Rheumatoid arthritis | 18%
High bone turnover rate | 4%

Because of inherent problems with temporal ambiguity we rejected the cross sectional studies. Because of data supporting the superiority of cohort studies over case control studies,47 we focused on the cohort studies. We identified seven articles assessing alcohol, but rejected one48 as data from this cohort were included in another study. Thus there were six articles about alcohol use. We identified one cohort assessing diabetes mellitus type II. We identified four relevant studies of osteoporosis in patients with spinal cord injury (SCI), one case control study and three cross-sectional studies.

Each study was assessed for quality using criteria suggested by Hayden & colleagues.24 Tables 4a–c and Table 5 present descriptive details.

Table 4a Cohort Studies Assessing Alcohol as a Risk Factor, Outcome Measure: Fracture Occurrence

Article | Population | Enrolled/Included in analysis | Duration of follow up | Alcohol Consumption Definition | Fracture Occurrence assessed | Covariates adjusted for | Quality Measurement | | Results
Article | Population | Enrolled/Included in analysis | Duration of follow up | Alcohol Consumption Definition | Fracture Occurrence assessed | Covariates adjusted for | Study Participation (SP) | Outcome Measurement (OM) | Results
Article | Population | Enrolled/Included in analysis | Duration of follow up | Alcohol Consumption Definition | Fracture Occurrence assessed | Covariates adjusted for | Study Attrition (SA) | Confounding Measurement (CM) | Results
Article | Population | Enrolled/Included in analysis | Duration of follow up | Alcohol Consumption Definition | Fracture Occurrence assessed | Covariates adjusted for | Prognostic Factor Measurement (PFM) | Analysis (A) | Results
Kanis, 2005^49^ | 3 cohort populations with mean ages 60, 70, 67 years | 5939/5939 | 27,968 person yrs | Units/day | Diary Medical Record Review | Age Low body weight Smoking | SP: Partly | OM: Partly | Alcohol intake of 3 units/day associated with increased RR of 1.91 for hip fracture. Alcohol intake of 4 units/day associated with increased RR of 1.81 for any osteoporotic fracture and increased RR of 2.84 for hip fracture.
Kanis, 2005^49^ | 3 cohort populations with mean ages 60, 70, 67 years | 5939/5939 | 27,968 person yrs | Units/day | Diary Medical Record Review | Age Low body weight Smoking | SA: Unsure | CM: Partly
Kanis, 2005^49^ | 3 cohort populations with mean ages 60, 70, 67 years | 5939/5939 | 27,968 person yrs | Units/day | Diary Medical Record Review | Age Low body weight Smoking | PFM: Yes | A: Yes
Roy, 2003^50^ | European men mean age 63.1 years | NR/3173 | 3.8 years | 5–6, 3–4, 1–2 days/wk | X-ray | Age Low body weight Inactivity Smoking Low calcium intake | SP: Partly | OM: Yes | Alcohol intake was not associated with a significant increase in risk of vertebral fracture.
Roy, 2003^50^ | European men mean age 63.1 years | NR/3173 | 3.8 years | 5–6, 3–4, 1–2 days/wk | X-ray | Age Low body weight Inactivity Smoking Low calcium intake | SA: Unsure | CM: Yes | Alcohol intake was not associated with a significant increase in risk of vertebral fracture.
Roy, 2003^50^ | European men mean age 63.1 years | NR/3173 | 3.8 years | 5–6, 3–4, 1–2 days/wk | X-ray | Age Low body weight Inactivity Smoking Low calcium intake | PFM: Yes | A: Partly | Alcohol intake was not associated with a significant increase in risk of vertebral fracture.
Holdrup, 1999^51^ | Pooled data from 3 Danish cohorts mean age 50.5 years | 17,868/17,868 | 13.6 years | Weekly number & kind of drinks | Administrative data Medical Record Review | Age Low body weight Inactivity Smoking | SP: Partly | OM: Yes | The relative risk of hip fracture was increased for men who drank 4 or more units per day (RR=1.75) and increased with increasing numbers of drinks/week (RR 5.28 for >10 units/day)
Holdrup, 1999^51^ | Pooled data from 3 Danish cohorts mean age 50.5 years | 17,868/17,868 | 13.6 years | Weekly number & kind of drinks | Administrative data Medical Record Review | Age Low body weight Inactivity Smoking | SA: Partly | CM: Partly | The relative risk of hip fracture was increased for men who drank 4 or more units per day (RR=1.75) and increased with increasing numbers of drinks/week (RR 5.28 for >10 units/day)
Holdrup, 1999^51^ | Pooled data from 3 Danish cohorts mean age 50.5 years | 17,868/17,868 | 13.6 years | Weekly number & kind of drinks | Administrative data Medical Record Review | Age Low body weight Inactivity Smoking | PFM: Yes | A: Yes | The relative risk of hip fracture was increased for men who drank 4 or more units per day (RR=1.75) and increased with increasing numbers of drinks/week (RR 5.28 for >10 units/day)

BMD=Bone Mass Density, NR=Not Reported, OP=Osteoporosis, RR=Relative Risk

Table 4b Cohort Studies Assessing Alcohol as a Risk Factor, Outcome Measure: BMD

Article | Population | Enrolled/Included in analysis | Duration of follow up | Alcohol Consumption Definition | BMD | | | Covariates adjusted for | Quality Measurement | | Results
Article | Population | Enrolled/Included in analysis | Duration of follow up | Alcohol Consumption Definition | Site | T-score | Reference Standard | Covariates adjusted for | Study Participation (SP) | Outcome Measurement (OM) | Results
Article | Population | Enrolled/Included in analysis | Duration of follow up | Alcohol Consumption Definition | Site | T-score | Reference Standard | Covariates adjusted for | Study Attrition (SA) | Confounding Measurement (CM) | Results
Article | Population | Enrolled/Included in analysis | Duration of follow up | Alcohol Consumption Definition | Site | T-score | Reference Standard | Covariates adjusted for | Prognostic Factor Measurement (PFM) | Analysis (A) | Results
Naves, 2005^53^ | Spanish men with mean age of 64 years | 229/150 | 4 years | Units, unit= 10 grams | Femur Spine | <−2.5=OP | Unclear | Age Low body weight Inactivity Smoking Low Calcium Intake Family History of OP fracture | SP: Yes | OM: Partly | Alcohol intake not significantly associated with change in BMD
Naves, 2005^53^ | Spanish men with mean age of 64 years | 229/150 | 4 years | Units, unit= 10 grams | Femur Spine | <−2.5=OP | Unclear | Age Low body weight Inactivity Smoking Low Calcium Intake Family History of OP fracture | SA: Yes | CM: Yes | Alcohol intake not significantly associated with change in BMD
Naves, 2005^53^ | Spanish men with mean age of 64 years | 229/150 | 4 years | Units, unit= 10 grams | Femur Spine | <−2.5=OP | Unclear | Age Low body weight Inactivity Smoking Low Calcium Intake Family History of OP fracture | PFM: Yes | A: Partly | Alcohol intake not significantly associated with change in BMD
Bakhireva 2004^54^ | American men with mean age of 70.8 years | 818/507 | 4 years | Drink >=3 days/wk v. <=2 days/wk | Femur Spine | <=−2=OP | Male | Age Low body weight Weight loss Inactivity Smoking Low calcium intake | SP: Yes | OM: Yes | Alcohol intake >=3 days/wk associated with decreased odds of bone loss at femoral neck (OR 0.68), but not at the spine
Bakhireva 2004^54^ | American men with mean age of 70.8 years | 818/507 | 4 years | Drink >=3 days/wk v. <=2 days/wk | Femur Spine | <=−2=OP | Male | Age Low body weight Weight loss Inactivity Smoking Low calcium intake | SA: Partly | CM: Yes | Alcohol intake >=3 days/wk associated with decreased odds of bone loss at femoral neck (OR 0.68), but not at the spine
Bakhireva 2004^54^ | American men with mean age of 70.8 years | 818/507 | 4 years | Drink >=3 days/wk v. <=2 days/wk | Femur Spine | <=−2=OP | Male | Age Low body weight Weight loss Inactivity Smoking Low calcium intake | PFM: Partly | A: Partly | Alcohol intake >=3 days/wk associated with decreased odds of bone loss at femoral neck (OR 0.68), but not at the spine
Hannan, 2000^55^ | Elderly American men | NR/278 | 4 years | Current vs. non user, grams/wk | Femur Spine | NR | NA | Age Low body weight Weight loss Inactivity Smoking Vitamin D deficiency Low calcium intake | SP: Yes | OM: Yes | Alcohol intake >= 7oz/wk associated with significant decrease in BMD at the radius, but not at the femoral neck or lumbar spine
Hannan, 2000^55^ | Elderly American men | NR/278 | 4 years | Current vs. non user, grams/wk | Femur Spine | NR | NA | Age Low body weight Weight loss Inactivity Smoking Vitamin D deficiency Low calcium intake | SA: Partly | CM: Yes | Alcohol intake >= 7oz/wk associated with significant decrease in BMD at the radius, but not at the femoral neck or lumbar spine
Hannan, 2000^55^ | Elderly American men | NR/278 | 4 years | Current vs. non user, grams/wk | Femur Spine | NR | NA | Age Low body weight Weight loss Inactivity Smoking Vitamin D deficiency Low calcium intake | PFM: Yes | A: Yes | Alcohol intake >= 7oz/wk associated with significant decrease in BMD at the radius, but not at the femoral neck or lumbar spine

BMD=Bone Mass Density, NR=Not Reported, NA=Not applicable, OP=Osteoporosis

Table 4c Cohort Studies Assessing Diabetes Type II or NOS as a Risk Factor, Outcome Measure: BMD

Article | Population | Enrolled/Included in analysis | Duration of follow up | Presence of Diabetes Defined | BMD | | | Covariates adjusted for | Quality Measurement | | Results
Article | Population | Enrolled/Included in analysis | Duration of follow up | Presence of Diabetes Defined | Site | T-score | Reference Standard | Covariates adjusted for | Study Participation (SP) | Outcome Measurement (OM) | Results
Article | Population | Enrolled/Included in analysis | Duration of follow up | Presence of Diabetes Defined | Site | T-score | Reference Standard | Covariates adjusted for | Study Attrition (SA) | Confounding Measurement (CM) | Results
Article | Population | Enrolled/Included in analysis | Duration of follow up | Presence of Diabetes Defined | Site | T-score | Reference Standard | Covariates adjusted for | Prognostic Factor Measurement (PFM) | Analysis (A) | Results
Schwartz, 2005^56^ | American men with mean age of 73.8 years | NR/998 | 4 years | History Blood work (FBG) (75gOGTT) | Femur | NR | NA | Age, Inactivity Low body weight Weight Loss Corticosteroid use Smoking Low calcium intake | SP: Yes | OM: Yes | Diabetes type 2 not associated with significant change in BMD
Schwartz, 2005^56^ | American men with mean age of 73.8 years | NR/998 | 4 years | History Blood work (FBG) (75gOGTT) | Femur | NR | NA | Age, Inactivity Low body weight Weight Loss Corticosteroid use Smoking Low calcium intake | SA: Yes | CM: Yes | Diabetes type 2 not associated with significant change in BMD
Schwartz, 2005^56^ | American men with mean age of 73.8 years | NR/998 | 4 years | History Blood work (FBG) (75gOGTT) | Femur | NR | NA | Age, Inactivity Low body weight Weight Loss Corticosteroid use Smoking Low calcium intake | PFM: Yes | A: Yes | Diabetes type 2 not associated with significant change in BMD

BMD=Bone Mass Density, NR=Not Reported, NA=Not Applicable, OP=Osteoporosis, FBG=Fasting Blood Glucose, OGTT=Oral Glucose Tolerance Test

Table 5 Studies Assessing Spinal Cord Injury as a Risk Factor, Outcome Measure: BMD and/or Fracture Occurrence

Article | Population | Study Design | Cases /Controls Included OR Sample Size | Spinal Cord Injury Definition | BMD | | | Fracture Occurrence Assessed | Covariates adjusted for | Quality Measurement | | Results
Article | Population | Study Design | Cases /Controls Included OR Sample Size | Spinal Cord Injury Definition | Site | T-score | Reference Standard | Fracture Occurrence Assessed | Covariates adjusted for | Study Participation (SP) | Outcome Measurement (OM) | Results
Article | Population | Study Design | Cases /Controls Included OR Sample Size | Spinal Cord Injury Definition | Site | T-score | Reference Standard | Fracture Occurrence Assessed | Covariates adjusted for | Study Attrition (SA) | Confounding Measurement (CM) | Results
Article | Population | Study Design | Cases /Controls Included OR Sample Size | Spinal Cord Injury Definition | Site | T-score | Reference Standard | Fracture Occurrence Assessed | Covariates adjusted for | Prognostic Factor Measurement (PFM) | Analysis (A) | Results
Jones, 2002[#1083] | SCI patients in New Zealand, mean age 32 years | Case Control | 17 cases 17 controls | Descriptive: Number of quadriplegic/para plegic; incomplete v. complete | Spine, Femur Radius, Finger Calcaneus Total body, arms, legs | <−2.5=OP | Young Adult Mean | Not assessed | Age Low body weight Inactivity | SP: Partly | OM: Partly | BMD values of total body, leg, and hip were significantly lower in SCI patients than in the controls
Jones, 2002[#1083] | SCI patients in New Zealand, mean age 32 years | Case Control | 17 cases 17 controls | Descriptive: Number of quadriplegic/para plegic; incomplete v. complete | Spine, Femur Radius, Finger Calcaneus Total body, arms, legs | <−2.5=OP | Young Adult Mean | Not assessed | Age Low body weight Inactivity | NA | CM: No | BMD values of total body, leg, and hip were significantly lower in SCI patients than in the controls
Jones, 2002[#1083] | SCI patients in New Zealand, mean age 32 years | Case Control | 17 cases 17 controls | Descriptive: Number of quadriplegic/para plegic; incomplete v. complete | Spine, Femur Radius, Finger Calcaneus Total body, arms, legs | <−2.5=OP | Young Adult Mean | Not assessed | Age Low body weight Inactivity | PFM: Partly | A: Yes | BMD values of total body, leg, and hip were significantly lower in SCI patients than in the controls
Lazo, 2001[#1386] | Veteran SCI patients associated with the Hines VA, median age 55 years | Cross Sectional | 45 | American Spinal Injury Association Classification | Femur | NR | Male | X-ray Diary | Age | SP: Partly | OM: Yes | Controlling for age and SCI duration, each unit t-value decrement in BMD at the femoral neck increased the risk of fracture 2.8 times.
Lazo, 2001[#1386] | Veteran SCI patients associated with the Hines VA, median age 55 years | Cross Sectional | 45 | American Spinal Injury Association Classification | Femur | NR | Male | X-ray Diary | Age | NA | CM: No | Controlling for age and SCI duration, each unit t-value decrement in BMD at the femoral neck increased the risk of fracture 2.8 times.
Lazo, 2001[#1386] | Veteran SCI patients associated with the Hines VA, median age 55 years | Cross Sectional | 45 | American Spinal Injury Association Classification | Femur | NR | Male | X-ray Diary | Age | PFM: Yes | A: Yes | Controlling for age and SCI duration, each unit t-value decrement in BMD at the femoral neck increased the risk of fracture 2.8 times.
Sabo, 2001[#1380] | Caucasian SCI patients <50 years living in Germany ; mean age 32 | Cross Sectional | 46 | Frankel Score, Neuro Level Assessment | Spine, Femur, Radius | Z-score, NR | Age-related Reference | Not assessed | | SP: No | OM: Yes | Compared with age-matched reference values, SCI patients had decreased BMD in the proximal femur and distal forearm. Post-operative immobilization and complete lesions were associated with lower BMD.
Sabo, 2001[#1380] | Caucasian SCI patients <50 years living in Germany ; mean age 32 | Cross Sectional | 46 | Frankel Score, Neuro Level Assessment | Spine, Femur, Radius | Z-score, NR | Age-related Reference | Not assessed | | NA | CM: No | Compared with age-matched reference values, SCI patients had decreased BMD in the proximal femur and distal forearm. Post-operative immobilization and complete lesions were associated with lower BMD.
Sabo, 2001[#1380] | Caucasian SCI patients <50 years living in Germany ; mean age 32 | Cross Sectional | 46 | Frankel Score, Neuro Level Assessment | Spine, Femur, Radius | Z-score, NR | Age-related Reference | Not assessed | | PFM: Yes | A: Partly | Compared with age-matched reference values, SCI patients had decreased BMD in the proximal femur and distal forearm. Post-operative immobilization and complete lesions were associated with lower BMD.
Demirel, 1998[#1382] | SCI patients from the Istanbul Physical Medicine and Rehabilitation Centre; mean age 36 | Cross Sectional | 32 | American Spinal Injury Association criteria for level of injury | Arms, Legs | Z-score, NR | Age- matched Z-score | Not assessed | Age Low body weight High bone turnover rate | SP: Partly | OM: Partly | BMD values were significantly higher in the upper extremities than in the lower extremities in paraplegic patients and BMD values in the upper extremities were significantly lower in quadriplegics compared to paraplegics.
Demirel, 1998[#1382] | SCI patients from the Istanbul Physical Medicine and Rehabilitation Centre; mean age 36 | Cross Sectional | 32 | American Spinal Injury Association criteria for level of injury | Arms, Legs | Z-score, NR | Age- matched Z-score | Not assessed | Age Low body weight High bone turnover rate | NA | CM: No
Demirel, 1998[#1382] | SCI patients from the Istanbul Physical Medicine and Rehabilitation Centre; mean age 36 | Cross Sectional | 32 | American Spinal Injury Association criteria for level of injury | Arms, Legs | Z-score, NR | Age- matched Z-score | Not assessed | Age Low body weight High bone turnover rate | PFM: Yes | A: Partly

SCI=Spinal Cord Injury, BMD=Bone Mass Density, NR=Not Reported, NA=Not applicable, OP=Osteoporosis

### SYNTHESIS

#### Alcohol Use and Osteoporotic Fracture

Three articles assessed the relationship between alcohol intake and osteoporotic fractures.49–51 Use of this outcome measure means that alcohol’s effect on bone density and its known effect on predisposing to falls are both included in the association. It was not possible to pool studies as the articles measure the exposure variable, alcohol use, in different ways: self report of units per day, days per week, or weekly number and kind of drinks. The measurement of alcohol exposure is known to be very sensitive to how self-report questions are asked.52 Study size was in general large, with 3,000–17,800 participants. On the Hayden items, these three studies scored modestly, with only 2 or 3 items being scored as fully satisfied, the remaining, being partly satisfied or unsure.

The two studies that assessed the association of units per day of alcohol intake and hip fracture both reported a statistically significant association. In the first of them, which also combined several other studies (in Canada, Australia, and the Netherlands) into a single analysis, assessed the relationship between self-reported alcohol use and hip fracture or osteoporotic fracture in about 6,000 men followed on average about 4 years.49 Alcohol use was measured once at entry and fractures were assessed by self-report with medical record verification. In a multivariate analysis adjusted for age, body mass index, and smoking (but not physical activity), a statistically significant association was seen in alcohol intake exceeding 3 units per day (3 units/day, RR hip fracture=1.91; 4 units/day, RR hip fracture=2.84, RR any osteoporotic fracture=1.81).

The second study, three cohorts in Copenhagen that were originally assembled to assess cardiovascular disease were re-assessed for the incidence of hip fracture as determined by inpatient admission for same in a national database of hospital discharges.51 More than 17,000 men were followed for 10 or more years. Alcohol intake was measured once, at entry into the study. In multivariate models adjusted for age, physical activity, body mass index, and other variables, a statistically significant association between baseline self-reported alcohol use and hip fracture was seen for categories of drinking exceeding 4 units per day (4–6 units/day, RR=1.75; 6–10 units/day, RR=1.84, >10 units/day, RR=5.28).

The third study to assess the relationship between alcohol intake and fracture came from the European Prospective Osteoporosis Study, which enrolled 3,173 men and followed them for about 4 years.50 Alcohol use was measured once at entry and was reported as frequency in days per week. Vertebral fractures were assessed with baseline and follow-up spinal radiographs. In bivariate analyses, increasing alcohol intake had modest associations with vertebral fractures (RR approximately 1.2 to 1.6) but these were not statistically significant.

#### Alcohol Use and Bone Mineral Density

Three articles assessed the relationship between alcohol use and bone mineral density as measured by DXA.53–55 Again, we could not pool these studies because they measured the use of alcohol in different ways. These studies were much smaller than the studies assessing fractures, with 150–507 persons being assessed. These studies scored somewhat better on the Hayden items, with 3, 4, and 5 items being scored as fully satisfied.

These three studies reached inconclusive results. A study of 278 from Framingham reported a statistically significant association between self-reported alcohol intake greater than seven ounces per week and decreased BMD only at the radial shaft. There were nonsignificant decreases in BMD at the trochanter and the lumbar spine.55

A study of the Rancho Bernardo cohort assessed 811 white men and reported a moderate positive effect of consuming alcohol three or more times per week on femoral neck BMD measured four years later. Non-significant positive associations were also reported for BMD measured at the spine and total hip.54 The third study in this group assessed 308 men in Spain.53 Participants completed a postal survey at entry and again at four years regarding health habits, including units per week of alcohol consumption. BMD was measured by DXA and performed at baseline and again at four years. No statistically significant association between alcohol intake and change in BMD was found.

#### Summary of Alcohol Use and Osteoporotic Fracture Evidence

Taken together, this group of studies suggests that alcohol intake is probably associated with an increase in hip fractures, but only at high rates of consumption. The lack of association reported in the European Prospective Osteoporotic study could be due to lack of specificity in the classification of alcohol consumption, as this study could not assess high rates of consumption. The available evidence fall short of proof because the strength of the association is modest (RR<2) and within the level where confounding is still a serious concern, and imprecision in the classification of alcohol consumption by self-report is present in all studies. With regard to BMD, these is no compelling evidence that alcohol intake is associated with lower BMD. (GRADE quality of evidence: Alcohol and Fractures = Low; Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate; Alcohol and BMD = Very Low; any estimate of effect is very uncertain.)

#### Diabetes Mellitus Type II

We identified only one cohort study that assessed the association between Type II diabetes mellitus and osteoporosis.56 This study assessed 998 older male participants in the Health ABC study, which was conducted in Pittsburgh and Memphis. The presence of diabetes was assessed by self-report and a fasting blood glucose (and follow-up two hour oral glucose tolerance test in selected participants). Bone density was determined using DXA at the proximal femur at entry and at follow-up. Duration of follow-up was four years. In multivariable models adjusting for age, baseline BMD, weight change, smoking status, renal status, and other variables, there was no association between the presence of diabetes and femoral neck or total hip BMD. On the Hayden criteria, this study scored very strongly, fully satisfying all six items.

#### Spinal Cord Injury

We identified four relevant studies of osteoporosis in patients with SCI, one case control study and three cross-sectional studies43,57–59 (Table 5). A large body of literature was also identified that assessed changes in BMD over time in patients with SCI.

The case control study compared 17 New Zealander SCI male patients between the ages of 17 and 52 who were matched for age, height, weight and time spent in physical activity with able-bodied male controls (many of the participants were elite sportsmen)57. Eleven of the SCI patients were tetraplegic and six paraplegic. BMD by DXA was measured for the total body, arms, legs, left hip and lumbar spine. There were significant differences in mean T-scores of the legs and hip between the SCI and control groups; and, mean t-scores in the SCI patients were consistent with osteoporosis in the legs and trochanter and osteopenia in the femoral neck and Wards triangle.

Further supporting the association between SCI and bone loss were the three cross-sectional studies. The first evaluated 41 veteran SCI patients with a mean age of 55 for predictors of osteoporotic fractures in SCI patients43. This study found a high prevalence of osteoporosis (61%) and osteopenia (19.5%) in the patients studied as well as a high prevalence of previous fracture (34%). Controlling for age and duration of SCI, BMD was a strong predictor of fracture with the risk of fracture increasing 2.6 times for each unit decrease in BMD T-score. Another cross-sectional study evaluated the BMD of 46 male SCI patients with a mean age of 32 and compared this to age-matched reference values and found significantly lower BMD Z-scores in the proximal femur and distal forearm but not in the lumbar spine58. Patients with a history of at least two weeks of immobilization after spine surgery had significantly lower BMD Z-scores in the proximal femur but not in the lumbar spine or distal forearm. Patients with complete SCI had lower BMD Z-scores in the lumbar spine compared to patients with incomplete SCI.

The last cross-sectional study evaluated 41 Turkish SCI patients of which 32 were male with a mean age of 34.4 years59. BMD Z-scores were significantly higher in the upper extremities for paraplegic patients when compared to tetraplegic patients; and, when evaluating paraplegic patients alone, BMD Z-scores were significantly higher in the upper extremities than the lower extremities. This study also demonstrated that BMD Z-scores were significantly higher in SCI patients with incomplete injuries versus those with complete injuries, in those with spastic versus flaccid paralysis, and in those with a shorter duration of injury.

As mentioned above, there were a number of longitudinal studies which evaluated changes in BMD for patients with SCI. These studies did not meet our criteria for in-depth review but overall were consistent in demonstrating decreasing BMD over time in SCI patients. Four of these studies assessed veterans with SCI.40–42,44 These studies support the hypothesis that SCI is a risk factor for osteoporosis.

#### Summary of Spinal Cord Injury and Osteoporosis or Osteoporotic Fracture

Taken together, these case-control and cross-sectional studies of SCI patients indicate that osteoporosis is significantly more likely in patients with SCI compared to non-SCI patients; that BMD worsens with duration of SCI; and, that decreases in BMD are more significant in bones distal to the SCI level. Fracture risk also appears elevated but the evidence is less robust.

### CONCLUSIONS

We found an older high quality meta analysis assessing numerous risk factors, and a limited number of articles specific to the risk factors alcohol use, diabetes mellitus type II and spinal cord injury. Based on these findings, our review suggests the following.

1. Strong predictors of an increased risk of osteoporosis in men include age, low body weight, physical inactivity, and weight loss. (GRADE quality of evidence = High; further research is very unlikely to change our confidence on the estimate of effect.)
2. Certain health conditions and medications also are strong or moderate predictors of an increased risk of osteoporosis in men. The most relevant to VA are prolonged systemic corticosteroid therapy and androgen deprivation (in the context of prostate cancer treatment). (GRADE quality of evidence = Moderate; further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.)
3. Alcohol use is probably associated with an increase in osteoporotic fractures, but is not clearly associated with an increase in osteoporosis as measured by BMD. (GRADE quality of evidence: Fractures = Moderate; further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate; BMD = Very Low; any estimate of effect is very uncertain.)
4. There is no evidence that diabetes mellitus type II is a significant risk factor for osteoporosis in men. (GRADE quality of evidence: Low; further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.)
5. Spinal cord injury is associated with an increase risk of osteoporosis and possibly osteoporotic fractures. (GRADE quality of evidence: BMD=Moderate; further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate; Fractures=Low; further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.)

## Key Question #2: Are there any validated tools (outside of DXA-determined central bone density) to screen for osteoporosis in men?

### CONCEPTUAL FRAMEWORK

The clinical diagnosis of osteoporosis in men can be made in two ways: through the occurrence of a fragility fracture or based on bone density criteria. Fragility fractures typically occur after a prolonged decrease in bone density and quality and are the hallmark of osteoporotic bone disease. In 1994, the World Health Organization defined osteoporosis as a bone mineral density of greater than 2.5 standard deviations (T-score, −2.5) below that of a young healthy population. While this definition was originally proposed for postmenopausal women, it has also been used to define osteoporosis in men.

Use of the WHO-recommended threshold T-score of −2.5 has substantially simplified the clinical diagnosis of osteoporosis. Establishing a T-score threshold is useful and practical because substantial evidence suggests that each standard deviation decrement in bone density roughly doubles fracture risk. As such, bone density is an excellent tool for identifying those at high risk for future fracture. A simple causal pathway with bone density as the key determining factor for fracture risk (i.e., from normal bone density, to osteoporotic bone density, to fracture) is one way to conceptualize the progression of osteoporotic bone disease (Figure 2a). However, while bone density measurement is one of the best tools currently available to assess fracture risk, it is at best an imperfect predictor of future fracture.

Figure 2a Bone Mineral Density-Centric Simple Model

Recent evidence, particularly from the National Osteoporosis Risk Assessment (NORA), which evaluated bone density and fracture history in over 200,000 postmenopausal women, reveals that the majority of osteoporotic fractures actually occur in those with a bone density T-score greater than −2.5. This is principally due to the poor sensitivity of central bone densitometry (reported to be around 70%) in identifying those who fracture. Although those without “osteoporosis” by T-score have lower rates of fracture than those with osteoporosis by T-score, there are much greater numbers of people with T-scores in the former category. These findings suggest that an alternate model of osteoporosis disease progression, one which incorporates multiple risk factors, is necessary to fully understand osteoporosis and identify those who will ultimately fracture (Figure 2b).

Figure 2b Multiple Risk Factor Model

In this context, screening is defined as performing a test to identify the condition in persons who are asymptomatic. An evaluation of a screening test requires its comparison to a “gold standard” method for identifying the condition.

As there are two commonly used “gold standard” reference tests (i.e., bone mineral density and fracture occurrence) for the diagnosis of osteoporosis, studies evaluating osteoporosis screening tests can be broadly divided into two categories: 1) those that assess a test against a bone density measurement; and 2) those that assess a test against a fracture occurrence. As such, diagnostic studies that evaluate screening tests against both bone density and studies that evaluate screening tests against fracture occurrence are important for review and included in our analysis.

As bone mineral density is often employed as a “gold standard” reference test, we do not specifically examine the test characteristics of central bone density (DXA) as a screening modality in this section. A recent cost-effectiveness analysis was presented in abstract form, at the American Society of Bone and Mineral Research60. This study used microsimulation Markov modeling to assess a policy of universal DXA screening in men combined with five years of bisphosphonate therapy for those men found to have osteoporosis (using the young female reference standard). For patients without a prior non-spine fracture, estimated costs per year of quality-adjusted life year varied from $248,000 to $143,000 to $78,000 to $30,000 by the age at which screening was done (65, 70, 75 and 80 years of age, respectively.) This indicates that universal screening with DXA is unlikely to be cost-effective. An evaluation of DXA, and the values used to diagnose osteoporosis and the evidence regarding the relationship with osteoporotic fracture occurrence, is the topic of Key Question #3, found on page 37.

The published literature suggests that male osteoporosis is a significantly underdiagnosed condition. While osteoporosis screening tools, such as quantitative ultrasound, have been assessed in women, little research has been performed on validating such screening tools in men. We reviewed the literature to identify studies that evaluated a screening osteoporosis index test against a reference test (i.e., bone density or fracture occurrence) in men. Our goal was to assess the test performance characteristics of tests in men and determine the validity of these tests for screening in male osteoporosis.

### DESCRIPTION OF EVIDENCE

Our search of PubMed identified 27 potentially relevant studies (See Figure 1, page 9). Descriptive information about these studies is displayed in Evidence Table 1 (see Appendix B). Of the 27 studies, 4 identified a veteran population. Twenty-one of the studies did not report the characteristics of the population; four had an Asian population; one had a Filipino population; one was other. The male sample size ranged from 33 to 6,860. In ten of the articles the population was unselected; eight included an elderly population; six used referrals; and three recruited patients from a specific clinic. Seven studies evaluated ultrasound (index test) against central dual x-ray absorptiometry (DXA, reference test); five studies evaluated osteoporosis screening questionnaires versus central DXA; and nine studies evaluated ultrasound versus fracture occurrence.

### QUALITY EVALUATION

Quality as assessed using the QUADAS instrument showed that almost all of the articles scored adequately on description of the selection criteria, the ability of the reference test to correctly classify the condition, the time period between the index test and the reference test, the sample receiving the reference test, the independence of the reference test, the description of the index test and the reference test, the generalizability to clinical practice, the reporting of uninterruptible test results. Conversely, almost no report indicated that interpretation of either the reference test or the index test was performed without knowledge (or “blind”) to the other test results. In 13 of 27 (48%), the representativeness of the enrolled population to a VA population was not clear. In almost half of studies (12 of 27), withdrawals from the study were either not explained or unclear, and in only half of studies (14 of 27) were patients selected representative of a population that might be eligible for screening in the VA. Thus, in this application, the QUADAS instrument had limited ability to distinguish between studies based on quality.

In terms of total score, none of the studies met all of the QUADAS criteria. However, 24 out of the 27 articles (88%) scored positive on at least 60% or more of the criteria. In studies of the efficacy of treatments, validation studies of the criteria of Jadad and of the Delphi list both found empirical evidence that a threshold of 60% of the criteria being met distinguished better quality studies from lesser quality studies.61,62 Until such time as empirical studies with QUADAS are available, it seems reasonable to use the 60% threshold for classifying studies with QUADAS. Hence, most of the studies we evaluated were of good quality.

### SCREENING TEST GROUPINGS

We found substantial heterogeneity in the original authors’ use of thresholds both for the index test and reference test. Additionally, several studies did not provide key information, such as sample size by group. We reviewed available data and used clinical judgment to group studies into categories of comparisons for further quantitative analysis (Tables 6a–c). Using central DXA as the reference standard, we analyzed studies evaluating: ultrasound versus central DXA; and questionnaires versus central DXA. Using fracture occurrence as the reference standard, we reviewed studies evaluating ultrasound versus fracture occurrence. We did not pool data for other index and reference test combinations because of the heterogeneous nature of the data.

Table 6a Study Test: Ultrasound vs. Reference Test: cDXA detailed comparison

STUDIES INCLUDED IN ANALYSIS
Article | Population | Study Test: Ultrasound | | | | Reference Test: cDXA | | | Data Pooling
Article | Population | Machine | Location | Measurement | Units | Machine | Location | Units | Sens | Spec | Variance | | Osteoporosis | Threshold
Article | Population | Machine | Location | Measurement | Units | Machine | Location | Units | Sens | Spec | Sens | Spec | Osteoporosis | Threshold
Gudmundsdottir, 2005^20^ | Unselected | Lunar Achilles+ | Calcaneus L | SI | T Score | Hologic QDR 4500 | LS, FN, TH | T Score | X | X | | | Total hip DXA T-score <−2.5 vs >=−2.5 | <0(risk) vs >=0(non-risk)
Gudmundsdottir, 2005^20^ | Unselected | Lunar Achilles+ | Calcaneus L | SI | T Score | Hologic QDR 4500 | LS, FN, TH | T Score | X | X | | | Total hip DXA T-score <−2.5 vs >=−2.5 | <−0.5(risk) vs >=−0.5(non-risk)
Gudmundsdottir, 2005^20^ | Unselected | Lunar Achilles+ | Calcaneus L | SI | T Score | Hologic QDR 4500 | LS, FN, TH | T Score | X | X | | | Total hip DXA T-score <−2.5 vs >=−2.5 | <−1.0(risk) vs >=−1.0(non-risk)
Gudmundsdottir, 2005^20^ | Unselected | Lunar Achilles+ | Calcaneus L | SI | T Score | Hologic QDR 4500 | LS, FN, TH | T Score | X | X | | | Femoral neck BMD T- score <=−2.5 vs >−2.5 | <0(risk) vs >=0(non-risk)
Gudmundsdottir, 2005^20^ | Unselected | Lunar Achilles+ | Calcaneus L | SI | T Score | Hologic QDR 4500 | LS, FN, TH | T Score | X | X | | | Femoral neck BMD T- score <=−2.5 vs >−2.5 | <−0.5(risk) vs >=−0.5(non-risk)
Gudmundsdottir, 2005^20^ | Unselected | Lunar Achilles+ | Calcaneus L | SI | T Score | Hologic QDR 4500 | LS, FN, TH | T Score | X | X | | | Femoral neck BMD T- score <=−2.5 vs >−2.5 | <−1.0(risk) vs >=−1.0(non-risk)
Gudmundsdottir, 2005^20^ | Unselected | Lunar Achilles+ | Calcaneus L | SI | T Score | Hologic QDR 4500 | LS, FN, TH | T Score | X | X | | | Central DXA T-score <−1.5 vs >=−1.5 | <0(risk) vs >=0(non-risk)
Kung, 2005^63^ | Elderly | Hologic Sahara | Calcaneus R | QUI (SI?) | T Score | Hologic QDR 2000+ | LS, F | T Score | X | X | X | X | Femoral Neck BMD T-score <=−2.5 vs >−2.5 | <= −1.2(risk) vs >−1.2(low risk)
Adler, 2003a 19 | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic QDR 4500 | LS, FN, TH | T Score | X | X | X | X | T-score <=−2.0 vs >−2.0 | <=−1.5(risk) vs >−1.5(non-risk)
Mulleman, 2002 64 | Referral | Lunar Achilles | Calcaneus | BUA, SOS & SI | T Score | Hologic QDR 2000 | LS, PF | T Score | X | X | | | BMD (FN, LS, TH) <−2.5 vs >=−2.5 | < −2.5(risk) vs >=−2.5 (non-risk)
Mulleman, 2002 64 | Referral | Lunar Achilles | Calcaneus | BUA, SOS & SI | T Score | Hologic QDR 2000 | LS, PF | T Score | X | X | | | SI T-score <−2.5 vs >=−2.5 | < −2.5(risk) vs >=−2.5 (non-risk)
Mulleman, 2002 64 | Referral | Lunar Achilles | Calcaneus | BUA, SOS & SI | T Score | Hologic QDR 2000 | LS, PF | T Score | X | X | | | BMD (FN, LS, TH) <−1.0 vs >=−1.0 | < −1.0 (risk) vs >=--1.0(non-risk)
Mulleman, 2002 64 | Referral | Lunar Achilles | Calcaneus | BUA, SOS & SI | T Score | Hologic QDR 2000 | LS, PF | T Score | X | X | | | SI T-score <−1.0 vs >=−1.0 | < −1.0 (risk) vs >=--1.0(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−1.5 vs >=−1.5 | <0(risk) vs >=0(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−1.5 vs >=−1.5 | <−0.5(risk) vs >=−0.5(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−1.5 vs >=−1.5 | <−1.0(risk) vs >=−1.0(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−1.5 vs >=−1.5 | <−1.5(risk) vs >=−1.5(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−1.5 vs >=−1.5 | <−2.0(risk) vs >=−2.0(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−1.5 vs >=−1.5 | <−2.5(risk) vs >=−2.5(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−2.0 vs >=−2.0 | <0(risk) vs >=0(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−2.0 vs >=−2.0 | <−0.5(risk) vs >=−0.5(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−2.0 vs >=−2.0 | <−1.0(risk) vs >=−1.0(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−2.0 vs >=−2.0 | <−1.5(risk) vs >=−1.5(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−2.0 vs >=−2.0 | <−2.0(risk) vs >=−2.0(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−2.0 vs >=−2.0 | <−2.5(risk) vs >=−2.5(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−2.5 vs >=−2.5 | <0(risk) vs >=0(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−2.5 vs >=−2.5 | <−0.5(risk) vs >=−0.5(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−2.5 vs >=−2.5 | <−1.0(risk) vs >=−1.0(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−2.5 vs >=−2.5 | <−1.5(risk) vs >=−1.5(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−2.5 vs >=−2.5 | <−2.0(risk) vs >=−2.0(non-risk)
Adler, 2001^27^ | Referral | Hologic Sahara | Calcaneus | QUI (SI?) | T Score | Hologic 1000-W | LS, FN, TH | T Score | X | X | X | X | Central DXA T-score <−2.5 vs >=−2.5 | <−2.5(risk) vs >=−2.5(non-risk)
STUDIES NOT INCLUDED IN ANALYSIS (no data on sensitivity/specificity)
Lynn, 2005^65^ | Elderly | Hologic Sahara | Calcaneus R | QUI (SI?) | Unitless | Hologic QDR 4500 W | LS, PF | T Score
Grampp, 2001^66^ | Unselected | Lunar Achilles | Calcaneus | SI | T Score | Hologic QDR 4500 | LS, FN | T Score
Montagnani, 2001^67^ | NR | DBM Sonic | Phalanx | UBPI, QUS | Unitless | Hologic QDR 4500 | LS, FN, TH | T Score

Sens=Sensitivity, Spec=Specificity, LS=Lumbar Spine, FN=Femoral Neck, TH=Total Hip, PF=Proximal Femur, SI=Stiffness Index, BUA=Broad-band ultrasound attenuation, SOS=Speed of sound, BMD=Bone Mass Density, UBPI=Ultrasound Bone Profile Index, US=Quantitative Ultrasound

Table 6b Study Test: Questionnaire vs. Reference Test: cDXA detailed comparison

STUDIES INCLUDED IN ANALYSIS
Article | Population | Study Test: Questionnaire | | | Reference Test: cDXA | | | Data Pooling
Article | Population | Name | Key Inputs | Units | Machine | Location | Units | Sens | Spec | Variance | | Threshold
Article | Population | Name | Key Inputs | Units | Machine | Location | Units | Sens | Spec | Sens | Spec | Threshold
Kung, 2005^63^ | Elderly | Clin Risk Assess Tool | Age, Weight | Score -11-10 | Hologic QDR 2000 + | LS, F | T Score | X | X | | | Femoral neck BMD T-score <=−2.5 vs >−2.5 | <=−1(risk) vs >−1 (low risk)
Li-Yu, 2005^15^ | Referral | Osteoporosis Screening Tool for Asians (OSTA) | Age, Weight | Lo, Med, Hi Risk | GE Lunar DPX-IQ | FN | T Score | X | X | X | X | BMD T-score <=−2.5 vs >−2.5 | <= −1 (high/medium risk) vs >−1(low risk)
Lynn, 2005^65^ | Elderly | Male Osteoporosis Screening Tool (MOST) | Weight, QUI^*^ | Score 0 − 8 | Hologic QDR 4500 W | LS, PF | T Score | X | X | | | Lumbar spine, total hip or Femoral neck BMD T-score <−2.5 vs >−2.5 | >3(risk) vs <=3(non-risk)
Adler, 2003b35 | Referral | Osteoporosis Screening Tool (OST ) | Age, Weight | Cutoff 3,2,1 | Hologic QDR 4500 | LS, FN, TH | T Score | X | X | X | X | DXA T-score <=−2.5 vs >−2.5 | <4(high/moderate risk) vs >=4(low risk)
Adler, 2003b35 | Referral | Osteoporosis Screening Tool (OST ) | Age, Weight | Cutoff 3,2,1 | Hologic QDR 4500 | LS, FN, TH | T Score | X | X | X | X | DXA T-score <=−2.5 vs >−2.5 | <= −2(high risk) vs >−2 (moderate/low risk)
STUDIES NOT INCLUDED IN ANALYSIS (no data on sensitivity/specificity)
Adler, 2003a19 | Referral | Questionnaire | Weight, Heel BMD, steroids, race | Score 0 –14 | Hologic QDR 4500 | LS, FN, TH | T Score

Sens=Sensitivity, Spec=Specificity, LS=Lumbar Spine, FN=Femoral Neck, TH=Total Hip, PF=Proximal Femur, BMD=Bone Mass Density

Table 6c Study Test: Ultrasound vs. Reference Test: Fracture Occurrence detailed comparison

Article | Population | Study Test: Ultrasound | | | | Reference Test: Fracture Occurrence
Article | Population | Machine | Location | Measurement | Units | Location & Details
Gonnelli, 2005^68^ | Referral | Lunar Achilles + | Calcaneus | SI | percent | Fragility Fractures: vertebral, wrist, pelvis, femur
Varenna, 2005^69^ | Other | Lunar Achilles | Calcaneus | SI, BUA, SOS | unitless, db/Mhz, m/s | Low energy fractures since age 50
Rothenberg, 2004^70^ | Other | Hologic Sahara | Calcaneus | Estimated BMD | gm/cm2, T score | Self reported fractures, followed up by phone call
Welch, 2004^71^ | Other | McCue CUBA | Calcaneus | BUA | db/MHz | Self reported vertebral, hip, wrist fractures or diagnosis of osteoporosis
Mulleman, 2002^64^ | Referral | Lunar Achilles | Calcaneus nondom | SI | T Score | Vertebral, other; low trauma; vertebral fractures: X-ray with > 15% decrease in vertebral height
Donaldson, 1999^72^ | Elderly | Walker Sonix 1001 | Calcaneus | BUA | db/MHz | Any since 50, By recall; minimum trauma
Stewart, 1995^73^ | Other | Walker Sonix UBA 575 | Calcaneus | BUA | db/MHz | Patients with vertebral fractures vs controls
Travers-Gustafson,. 1995^74^ | Elderly | Osteo-Technology Signet | Patella | AVU | m/sec | Fractures since age 40, experts assessed fracture reports, low trauma
Bauer2004^75^ | Elderly | Hologic Sahara | Calcaneus | BUA | db/MHz | Hip and non-spine fractures in older men

Sens=Sensitivity, Spec=Specificity, LS=Lumbar Spine, FN=Femoral Neck, TH=Total Hip, PF=Proximal Femur, BMD=Bone Mass Density

### CENTRAL DXA AS REFERENCE TEST

Ultimately, we were able to pool only studies evaluating calcaneal ultrasound versus central DXA and those evaluating Osteoporosis Self-Assessment Tool (OST) versus central DXA (Table 6a–b). There were studies comparing ultrasound to cDXA that we could not include in our pooled analysis because they lacked data to calculate the sensitivity and specificity.65–67 Details of these analyses are presented below and in graphical format, along with a pooled ROC curve from a recently published meta-analysis of the utility of calcaneal ultrasound versus central DXA in women,76 in the following series of figures (Figures 3a–d, 4, 5).

Figure 3a Sensitivity versus 1-Specificity: Pooled Results of Heel Ultrasound or OSTA Compared to cDXA

Figure 3b ROC Curve Comparing Quantitative Ultrasound to cDXA Using Three Different T-scores

Figure 3c ROC Curve Comparing Quantative Ultrasound to cDXA from Meta-Analysis of Nayak (2006)

Figure 3d ROC Curves Comparing Quantitative Ultrasound to cDXA: A Comparison of Figures 3a–c

Figure 4 ROC Curve Comparing OST to cDXA using Two Different T-Scores

Figure 5 ROC Curves and Individual Study Sensitivity versus 1-Specificity (All Studies)

#### Calcaneal Ultrasound versus Central DXA

Calcaneal ultrasound, in which an ultrasound probe is placed on either heel, has the advantages of being portable, inexpensive, and radiation-free. Ultrasound measurements are often reported as T-scores (standardized units) of the quantitative ultrasound index (QUI). However, there is no commonly accepted threshold for a positive QUI reading, and our review showed that thresholds from 0 to −2.5 have been used.

Given this heterogeneity in thresholds, we were able to incorporate data from only 3 studies for our summary sensitivity and specificity measurements.19,27,63 We found that using a calcaneal ultrasound T-score of −1.0, calcaneal ultrasound had a sensitivity of 75% and a specificity of 66% to diagnose bone density-determined osteoporosis (central DXA T-score of < −2.5) (Figure 3a). When the calcaneal ultrasound threshold was decreased to −1.5, specificity improved to 78% but sensitivity dropped to 47%. We were able to construct a ROC curve from one study evaluating male veterans27 (Figure 3b), which varied calcaneal ultrasound thresholds from −1.5 to −2.5. Superimposing these ROC curves onto a recently reported ROC curve of calcaneal ultrasound in primarily women (Figure 3c) showed these curves to be similar, suggesting that calcaneal ultrasound likely performs comparably in men as in women (Figure 3d).

#### The Osteoporosis Self-Assessment Tool (OST) versus Central DXA

The Osteoporosis Self-Assessment Tool, which uses a subject’s age and weight to develop a risk score (equation: [(weight in kilograms – age in years) x 0.2], truncated to an integer), is a simple test which has been primarily evaluated and validated in women. More recently, a number of evaluations have been performed in men, with particular attention to the veteran population.35 Similarly to calcaneal ultrasound, there is no commonly accepted OST risk score threshold. Our review showed that thresholds from −1 to 3 have been used (Table 6b).

Pooling data from two studies of evaluations of Asian men (Chinese and Filipino), we found that at an OST risk score of −1, the OST had a sensitivity of 81% and specificity of 68% to diagnose bone density-determined osteoporosis. In the only study of OST in Veterans (Figure 4), the authors found that at an OST threshold of 3, the OST had a sensitivity of 93% and specificity of 66%. Sensitivity decreased to 75% and specificity increased to 80% when the OST threshold was decreased to 1. Of note, at all thresholds evaluated, the OST had higher sensitivity and specificity than calcaneal ultrasound, although this analysis is limited by the paucity of data points available and therefore no definitive conclusions can be drawn.

Summary Figure 5 graphs all results from all articles with relevant data, and the meta-analytic result for the ROC curve in primarily women76 (data in red). The figure shows that all studies assessing ultrasound reported results that are close to the pooled ROC curve for primarily women. The studies assessing OST reported results above the pooled ROC curve, suggesting OST may be more accurate than ultrasound.

### FRACTURE OCCURRENCE AS REFERENCE TEST

Eighteen studies used fractures occurrence as the reference test, with: ten evaluating ultrasound as the index test; two evaluating quantitative CT, and one each evaluating peripheral bone density, central bone density, x-ray, bone structural parameters, linear photon absorptiometry, and a multivariate scoring model (Table 6c). However, we could not pool data from these studies given the heterogeneity of the data although we provide a qualitative assessment of studies evaluating ultrasound against fracture occurrence below. We narratively summarized the nine studies that assessed ultrasound to occurrence of fragility fractures.64,68–75

#### Calcaneal Ultrasound versus Fracture Occurrence

Calcaneal ultrasound appears to be independently associated with and moderately predictive of fragility fracture in men. One study found that each standard deviation reduction in ultrasound measurement resulted in an approximate two-fold increase in hip fractures that was independent of age and other clinical variables and comparable to findings in elderly women.69 Similarly, an abstract published from the ongoing and pivotal MrOS Study, a population-based study of older men, found that each SD reduction in calcaneal ultrasound measurement was associated with an increased risk of hip (relative hazard, 2.0, 1.3–3.5) and non-spine fracture (relative hazard, 1.7, 1.4–2.0).75 Finally, another study found that ultrasound stiffness parameters had a strong association (odds ratio 3.2, 2.3–4.5) with prior fragility fracture.68

More controversial is whether the combination of bone density measurements and calcaneal ultrasound to assess for fractures is better than either test alone. One study found that both bone mineral density of the hip (odds ratio, 3.4) and ultrasound (odds ratio, 3.2) were strongly associated with fragility fracture.68 If bone density and ultrasound results were combined, the odds ratio for fracture association increased to 6.1. However, an analysis of ROC curves for hip fracture prediction from the MrOS study for: ultrasound alone (AUC, 0.84); bone mineral density alone (AUC, 0.85); and the combination of the two (AUC 0.85) suggested that the combining ultrasound and bone mineral density was not superior to using either modality alone.75 As such, it remains unclear as to whether an optimal male osteoporosis screening program should include bone density, ultrasound, or a combination of these two or other test modalities.

### CONCLUSIONS

Although the limited number of studies published on male osteoporosis screening tools precludes drawing definitive conclusions on these tests, our review suggests the following:

1. There is no evidence to suggest that calcaneal ultrasound performs differently in men than in women. Our pooled data points and the ROC curve we constructed to evaluate calcaneal ultrasound against a reference standard of bone density appeared comparable to a recently published ROC curve on calcaneal ultrasound that included studies primarily evaluating women. In addition, we found evidence that calcaneal ultrasound measurements were predictive of or associated with fractures in men at similar levels as those published for women. As such, we find no evidence indicating that calcaneal ultrasound should perform any differently in men as it does in women. The available data fall short of proof, but suggest that calcaneal ultrasound performs comparably in men as in women. (GRADE quality of evidence = Moderate; further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.)
2. The OST appears to have comparable (and possibly better) test characteristics than calcaneal ultrasound in diagnosing DXA-determined osteoporosis. The OST, a questionnaire which incorporates only age and weight, appears to perform as well or better than ultrasound in predicting DXA-determined osteoporosis. Supporting this conclusion, one of the studies identified assessed Veterans, and found test characteristics similar to our pooled analysis. This simple tool appears promising and could potentially be easily incorporated into a mass osteoporosis screening program. However, caution must be exercised as two of the three studies we quantitatively analyzed enrolled exclusively men from Asia. In addition, all of these studies evaluated the OST against DXA, and not against fracture occurrence, which is the critical outcome of interest. Our results suggest that more evaluation of this test is urgently warranted and necessary. (GRADE quality of evidence = Low; further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.)
3. Although calcaneal ultrasound does not appear to be a particularly good test at diagnosing DXA-determined osteoporosis, it is a strong, independent predictor of fractures in men. Although ultrasound may not perform exceptionally well at predicting a particular bone mineral density score, it appears to perform well in identifying a population of patients who will fracture, the endpoint that clinicians and patients ultimately care about. Both bone density and ultrasound can identify populations who will fracture, although these populations do not appear to fully overlap. Ultrasound may be identifying deficits in other bone parameters, such as bone quality, which may not be identified through bone density measurement. However, as almost all clinical trials of osteoporosis drugs recruited patients based on a bone density score and not an ultrasound score, it remains to be determined if those identified at risk for fracture by ultrasound will benefit from our current osteoporosis drug armamentarium. This finding is likely to be true for all patients identified to be “at risk” through the screening modalities (e.g., osteoporosis screening questionnaires) evaluated in this review, as it is not clear that current pharmacologic interventions decrease fracture risk in such populations given the lack of clinical trial evaluation in these specific groups. (GRADE quality of evidence = Moderate; further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.)
4. Limited data are available on other screening modalities and there is a large gap in our understanding of osteoporosis screening tests in men. Our comprehensive review identified only 26 studies in total evaluating osteoporosis screening tests in men. We were only able to perform limited quantitative analyses on two screening tests: calcaneal ultrasound and the OST. It remains unclear if other screening tests, such as quantitative CT, other types of questionnaires, or peripheral bone density measurements, might also be useful as screening tests in men. As such, there is a large, and currently unmet, need for additional research in this field of study.
5. A majority of the studies compared a screening test against DXA and not fracture occurrence. Most of the studies we identified evaluated a screening test against the gold standard of central DXA rather than fracture occurrence. The relevant clinical outcome is fracture occurrence, and studies assessing their relationship are needed. In order to interpret the clinical utility of such studies, though, evidence is needed about the effectiveness of therapies to prevent fracture occurrence in men identified as high risk based on calcaneal ultrasound, or OST, etc.

## Key Question 3: What values of BMD determined by DXA (and by different DXA techniques) have been used to diagnose osteopenia and osteoporosis; and what is the evidence regarding the relationship between differing definitions and the development of osteoporotic fractures?

Our review identified 31 articles evaluating the association between BMD as measured by DXA and the risk of fractures in men. Most of these articles indicated that BMD is a strong predictor of fracture risk in men and femoral neck BMD is a stronger predictor than lumbar spine BMD. Almost all studies assessed BMD as a standardized measure (in terms of T-score or Z-score) and not in terms of grams of bone mineral content per centimeter squared.

Risk of fracture per standard deviation decrease in BMD varied by study. One large meta-analysis of 12 cohort studies77 found that the gradient of risk for an osteoporotic fracture per standard deviation decrease in z-score in men (“gradient of risk” = RR/SD) was 1.6 and the gradient of risk for a hip fracture per standard deviation decrease in z-score in men was 2.42. Another large prospective cohort study78 found a 3.2 time increased risk of hip fracture per sex-specific SD decrease in total hip BMD.

Virtually all studies evaluating the relationship between BMD and osteoporosis in men defined osteoporosis as a BMD more than 2.5 standard deviations below the mean for young adults (“T-score”). However, whether to use a young female or a young male reference range when evaluating BMD in men is an area of controversy that is not possible to resolve with existing data. In a summary statement from the International Conference on Osteoporosis in Men in 2002, international experts “agreed to disagree” on this issue, each marshalling data to support their own position.

In an article from this conference, a summary of the evidence favoring use of the female reference range was presented. Proponents of this cite studies that have demonstrated that measurement of BMD at the hip expressed as a T-score using the female reference standard predicts fracture risk similarly in men and women. By far the largest study identified was a meta-analysis of 12 cohort studies that collectively included 9891 men, 29082 women and 168,366 person years.77 The “gradient of risk” (RR/SD) for each SD decrease in BMD using sex and age-specific standard deviations (Z-scores) was virtually identical in men and women; and, was not significantly different from the “gradient of risk” using the standard deviation of a young female reference range (T-scores). For instance, in men the gradient of risk for osteoporotic fractures was 1.6 using a sex and age-specific reference range and was 1.55 using a young female reference range. In women, the gradient of risk for osteoporotic fractures was 1.53 using a sex and age-specific reference range and 1.56 using a young female reference range. Currently, this is the primary evidence behind the argument that the reference range used in men and women should be the same, and should be the female range. The study shows not only that gradient of risk is the same but also that the absolute risk is the same in men and women using the female range.

Additionally, some studies have demonstrated that men and women at the same age with the same absolute BMD at the hip have an equal likelihood of hip fracture.79 Thus, these experts argue that osteoporosis in men should be defined as it is in women, using T-scores derived from a young healthy female reference population.

Critics of this conclusion, raise several concerns. First, they argue that, despite the large numbers of patients included in this pooled analysis, the data are imprecise because different populations are mixed together. Important heterogeneity in effect may be obscured. Second, these critics point to a large prospective study demonstrating a much stronger relationship in men than in women between hip BMD & subsequent fracture78 as evidence that there are important gender differences to be discovered and dealt with. Furthermore, they point out that using a young female reference range underestimates the expected prevalence of osteoporosis in men. In one study by Melton80 evaluating the association of BMD with hip fracture risk, the prevalence of osteoporosis in men using a young healthy male reference range was 19.4% versus only 3.4% using a young healthy female reference range. In another study by Falkner,81 prevalence estimates for osteoporosis in men differed depending on which reference range was utilized. This study also raised the question as to whether using the standard definition of osteoporosis (more than 2.5 standard deviations below the mean) is appropriate in men since the T-scores that best corresponded to the lifetime risk for osteoporotic fracture in men were significantly different from −2.5 (−1.9 using young male reference ranges and −1.5 using young female reference ranges). Thus, there is evidence that using female-specific reference ranges may significantly under detect osteoporosis in men and result in fewer men being identified who may, in fact, be at risk for osteoporotic fracture and might benefit from treatment.

Proponents of the female standard respond to these arguments by highlighting the fact that there are few data relating use of the male reference range and the 5- or 10-year risk of fracture.

Whether to utilize gender-specific reference ranges to determine T-scores when screening for osteoporosis remains an area of uncertainty and awaits further prospective studies evaluating the association of fracture and BMD. But a principle of screening is that it should be performed only when there is an effective health care strategy for early treatment.82 Therefore, when deciding which reference range to choose given current limited information, it is helpful to evaluate how subjects were identified as candidates for osteoporosis therapies in randomized controlled trials that have demonstrated a benefit in reducing risk of osteoporotic fractures. In other words, a screening program to identify Veterans with osteoporosis would be rooted in current evidence when it identifies persons who are most similar to the subjects enrolled in the RCTs that we rely on to guide treatment. Table 7 presents information from all of the RCTs identified in an ongoing systematic review of therapies for osteoporosis (Comparative Effectiveness Review of Pharmacologic Therapies for Low Bone Density, Southern California Evidence Based Practice Center Draft Report) that reported data specific to men, using as outcome either fractures or any of several intermediate outcomes. Many of these studies used the existing presence of osteoporotic fractures as an entry criterion, and in that case the concept of “screening” does not apply. But in those studies that used BMD as measured by DXA as the entry criterion for low bone density, all used T-scores using the young male reference standard. Therefore, this is evidence that men identified with low bone density/osteoporosis using the young male reference standard (which is a larger percentage of the potentially osteoporotic population than would be identified using the young female standard, as discussed previously) will benefit from treatment. This does not account for the potential for heterogeneity in treatment effects.27,66 In some RCTs, it has been shown that studies reporting a benefit in the enrolled population actually provided large benefit to only a portion of that population – usually the most severely affected – while providing no benefit or actually harming other enrolled patients, although the net “overall” result was still positive. Whether there is heterogeneity in treatment effects in the RCTs of treatment for men with low bone density is not known. However, until more definitive evidence is available, we believe it is most logically consistent for VA to identify men who might benefit from treatment for osteoporosis by adhering to the same conditions as were used in RCTs of osteoporosis treatment; namely, the young male reference standard. (GRADE quality of evidence = Low; further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.)

Table 7 Entry Criteria of Trials Reporting Efficacy of Osteoporosis Treatment in Men

Studies that Use Fracture Reduction as Outcome
Study | DXA Site | T-score | Reference | Includes Fragility Fracture | Treatment Assessed
Ringe 2006^83^ | Lumbar Spine | <=−2.5 | male | with or without | risedronate
Ringe 2006^83^ | Femoral Neck | <=−2.0 | male | with or without | risedronate
Kaufman, 2005^84^ | Lumbar Spine or Proximal Femur | <=−2.0 | male | no | teriparatide
Ringe, 2004^85^ & Ringe, 2001^86^ | Lumbar Spine | <−2.5 | male | no | alendronate
Orwoll, 2003^54^ | Proximal Femur or Lumbar Spine | <−2.0 | male | no | teriparatide
Orwoll, 2000^87^ | Femoral neck and Lumbar Spine | <=−2.0 FM & <=−1.0 LS | male | no | alendronate
Orwoll, 2000^87^ | Femoral neck | <=−1.0 | male | no | alendronate
Studies that Use Other Outcomes
| DXA Site | T-score | Reference | Includes Fragility Fracture | Treatment Assessed | Outcome
Shimon, 2005^88^ | Lumbar Spine or Femoral Neck | <=−2.0 | male | not inclusion criteria but reported in Table 1 | alendronate | BMD lumbar spine & femoral neck
Kurland, 2000^89^ | Lumbar Spine or Femoral Neck | <=−2.5 | male | not inclusion criteria but reported | parathyroid hormone | BMD lumbar spine & femoral neck
Toth, 2005^57^ | Lumbar Spine or Femoral Neck | <−2.5 | gender specific | no | intranasal salmon calcitonin therapy | BMD lumbar spine & femoral neck
Drake, 2003^90^ | Femoral Neck and Lumbar Spine | <−2.0 FM & <−1.0 LS | male | no | alendronate | BMD lumbar spine & total spine
Drake, 2003^90^ | Femoral Neck | <−1.0 | male | yes | alendronate | BMD lumbar spine & total spine
Laroche, 1998^91^ | Lumbar Spine | <−2.5 | | lumbar spine BMD and/or fractures | fluoride, etidronate, calcitron | BMD
Trovas, 2002^92^ | Lumbar Spine or Femoral Neck | <−2.5 | male | no | nasal spray salmon calcitonin | BMD spine & femoral neck
Gonnelli, 2003^93^ | Lumbar Spine or Femoral Neck | <=−2.5 | male | not inclusion criteria, but reported | alendronate | BMD lumbar spine, femoral neck, total hip