# METHODS

## Topic Development

This project was nominated by William Duncan, MD, for the Evidence Synthesis Project. Key questions were discussed and finalized during a conference call that included the Steering Committee of the Evidence Synthesis Project, Dr. Duncan, and the VA Greater Los Angeles project site director. The final key questions are:

1. What are the prevalence of and risk factors for osteopenia, osteoporosis and osteoporotic fractures among men in general and among male Veterans specifically?
2. Are there any validated tools (outside of central bone density) to screen for osteoporosis in men?
3. What values of BMD determined by DXA (and by different DXA techniques) have been used to diagnose osteopenia and osteoporosis; and what is the evidence regarding the relationship between differing definitions and the development of osteoporotic fractures?

## Search Strategy

Our library searches began in June, 2006, with a search of PubMed.

The search strategy is listed below:

DATABASE SEARCHED & TIME PERIOD COVERED: PUBMED – 1990–2006

LIMITERS: ENGLISH, HUMAN, MALE

SEARCH STRATEGY:

osteoporosis[majr] OR osteoporosis[ti]

AND

male[tiab] OR men[tiab] OR gender

AND

risk factors[majr] OR risk*[tiab]

AND

bone mineral density OR bone*[ti] OR risk*[ti] OR fractur*[ti]

NOT

Results of previous searches

NUMBER OF ITEMS RETRIEVED: 508

In addition to our PubMed search, we performed reference mining of retrieved articles, references of prior reviews, and solicited articles from experts.

## Study Selection

Four trained researchers (working in groups of two) reviewed the list of titles and selected articles for further review. Each group of two consisted of an endocrinologist trained in the critical examination of literature and a fellowship-trained health services research general internist. Each article retrieved was reviewed with a brief screening form (see Appendix A) that collected data on prevalence and incidence, risk fractures, diagnostic tools, associations between bone mass density levels (BMD) as determined by dual energy X-ray absorptiometry (DXA), study design, and whether or not the subjects in the study were Veterans. To be included in our evidence report, a study had to measure incidence, prevalence, or risk factors for osteoporosis in men; or, a comparison of two different methods of assessing for the presence of osteoporosis in men; or, provide data on different values of BMD as determined by DXA and risk of osteoporotic fractures in men. Eligible study designs included controlled clinical trials, cohort studies and case series, case control studies, and systematic reviews/meta-analyses. Case reports, non-systematic reviews, letters to the editor and other similar contributions were excluded.

## Data Abstraction

Data were independently abstracted by an endocrinologist and a general internist/health services researcher, with consensus resolution. The following data were abstracted from included trials: study test and site, reference test and site, population, sample size, patient characteristics, region, and outcome reporting. Data abstraction forms are provided in Appendix A.

For diagnostic accuracy studies, a statistician extracted data. For each selected study, the sample size, sensitivity and specificity at each quantitative ultrasound or questionnaire threshold were extracted. The standard error of sensitivity and specificity were calculated as variance_sens =_ p_i_*(1−p_i_)/n_i_ where p_i is the_ sensitivity for study i and n_i_ is the number of people classified as having the disease for study i. If a study did not report the sensitivity or specificity and if they could not be calculated from the given data, the study was excluded from analysis. We contacted the original authors of some studies to obtain the sample sizes per group needed to perform this calculation.

## Quality assessment

To assess internal validity of diagnostic studies, we used the QUADAS, a tool for Quality Assessment of studies of Diagnostic Accuracy included in Systematic Reviews (see Appendix A). We abstracted data on representativeness of patients to those who will receive the test in practice; clarity of selection criteria; likelihood of reference test to correctly classify the condition; time frame between reference test and study test; whether or not the entire or randomized group of the sample received verification using the reference test; whether patients received the same reference test regardless of the study test result; independence of the reference test from the study test; ability to replicate study and reference test based on detail provided in the article; study test results interpreted blinded from reference standard and vice versa; replicability of results when test is used in practice; and whether intermediate test results were reported; withdrawals from the study explained.

To assess internal validity of studies of risk or prognosis, we used the criteria proposed by Hayden and colleagues24 (see Appendix A). We abstracted data on study participation; study attrition, prognostic factor measurement; outcome measurement; confounding measurement and account; and analysis.

## Rating the body of evidence

We assessed the overall quality of evidence for outcomes using a method developed by the Grade Working Group, which classified the grade of evidence across outcomes according to the following criteria:25

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Very Low = Any estimate of effect is very uncertain.

GRADE also suggests using the following scheme for assigning the “grade” or strength of evidence:

Criteria for assigning grade of evidence

Type of evidence

Randomized trial = high

Observational study = low

Any other evidence = very low

Decrease grade if:

- Serious (−1) or very serious (−2) limitation to study quality
- Important inconsistency (−1)
- Some (−1) or major (−2) uncertainty about directness
- Imprecise or sparse data (−1)
- High probability of reporting bias (−1)

Increase grade if:

- Strong evidence of association-significant relative risk of > 2 (< 0.5) based on consistent evidence from two or more observational studies, with no plausible confounders (+1)
- Very strong evidence of association-significant relative risk of > 5 (< 0.2) based on direct evidence with no major threats to validity (+2)
- Evidence of a dose response gradient (+1)
- All plausible confounders would have reduced the effect (+1)

For this report, we used both this explicit scoring scheme and the global implicit judgment about “confidence” in the result. Where the two disagreed, we went with the lower of the two classifications.

## Data Synthesis

Of the articles that were determined to be clinically eligible, thresholds for determining osteoporosis (in terms of T-scores) were reviewed across studies to see if they were comparable. First, we looked to see if the diagnostic method used was similar across studies. Then, within diagnostic method, we looked to see if the cutoff points analyzed were consistent across studies. Within comparable measures, we estimated a pooled random effects estimate26 of the sensitivity and specificity. ROC (receiver operating characteristic) curves were graphed. Pooled estimates from the meta analysis were plotted onto the ROC curves.

The remaining studies regarding diagnostic assessments were too heterogeneous to statistically pool, and we therefore summarized these narratively.

## Peer Review

This report was reviewed by our technical experts. Their comments were taken into consideration in our revision. Service as a technical expert does not imply endorsement of the report’s findings.