# INTRODUCTION

## Background

Although the Surgeon General’s recent report on osteoporosis stated that, “Strong bones (are) essential to overall health and quality of life,” it warned that, “The bone health status of Americans… is in jeopardy.”1 Traditionally, osteoporosis was viewed as a disease of women, but it has become clear that osteoporotic fractures result in substantial morbidity, mortality, and costs in men.2–6 A 60-year old man has a 25% lifetime risk of sustaining an osteoporotic fracture.7 The consequences of this fracture can be severe as the one-year mortality rate in men after hip fracture is twice that of women.8 With the aging of the population, rates of osteoporosis in men are expected to increase nearly 50% in the next 15 years and hip fractures rates are projected to double or triple by 2040.^1^

Furthermore, annual U.S. direct medical costs for osteoporosis exceed $17 billion9 and are expected to increase rapidly with an aging population.1 The percentage of costs directly attributable to men or veterans is unclear, although 25% of hip fractures, the fracture type associated with greatest costs due to hospitalization and long-term care, occur in men.5 This large and growing clinical and cost burden, combined with an environment of increasingly limited health care resources, strongly underlies the need to develop rational, evidence-based osteoporosis management strategies to obtain maximum benefit for every health care dollar spent.

Osteoporotic fractures may be particularly devastating in the veteran population as post-fracture inpatient mortality rates for Veterans are more than double that of the general population.10 An analysis of femoral bone mineral density data from the National Health and Nutrition Examination Survey (NHANES) III, a nationally-representative dataset, reported that 1 to 2 million American men over the age of 50 have osteoporosis and 8 to 13 million similarly-aged men have osteopenia, or low bone density.11 Applying prevalence data from this analysis to VA-specific enrollee data,12 it is possible that 200,000 to 400,000 veterans have osteoporosis and 2 to 3 million veterans have osteopenia. These estimates are likely conservative as Veterans have increased rates of co-morbid conditions compared to the general population.13

Despite the substantial advances in our understanding of osteoporosis over the last decade, there are no consensus guidelines on the assessment and management of male osteoporosis. Although osteoporosis management strategies have been evaluated in women,1,14–19 much less work has been done in this area in men.10,20,21 Lack of research in this area has led to considerable uncertainty regarding optimal osteoporosis strategies in men and Veterans. The VA Office of Quality and Performance and the U.S. Preventive Services Task Force offer no clinical practice guidelines on the management of osteoporosis in men. The National Osteoporosis Foundation offers no guidelines on screening for men, although it suggests that that all individuals be treated with osteoporosis medications if they have a pre-existing fragility fracture.22 The International Society for Clinical Densitometry suggests that all men over the age of 70 receive a DXA exam,23 although the effects of this recommendation have not been evaluated. As such, a significant gap in our understanding exists on how best to evaluate and manage osteoporosis in men.

As the largest integrated health care system in the U.S., serving a population that is more than 95% male and 80% over the age of 50,^12^ these issues are of particular concern and importance to the VA. In particular, identifying and implementing optimal strategies for osteoporosis management will be critically important over the next five to ten years as the “baby boomers” begin to reach retirement, an age when fracture risk dramatically increases in men. Given the large number of male veterans at high risk for osteoporosis who receive care through the VA, the VA is uniquely positioned and qualified to dramatically preserve and improve veteran and male skeletal health

In order to inform decision-making regarding potential VA screening guidelines for male osteoporosis, William Duncan, MD, PhD, the Acting Director of the VA Medical Service, and the VA HSR&D Service commissioned this literature review of the epidemiology and risk factors for osteoporosis, and validity of screening tools for male osteoporosis. This review is being performed as part of the Evidence Synthesis Project, an HSR&D-organized initiative to provide VA policymakers with high quality evidence reviews.

The purpose of this review is to analyze the literature in order to answer three key questions: 1) What is the epidemiology and what are the key risk factors for male osteoporosis?; 2) Are there any validated screening tools for osteoporosis in men (beyond DXA-assessed central bone density)?; and 3) What is the evidence regarding bone mineral density and fracture risk? The results of this review will be used to assist VA policy-makers in making evidence-based decisions on how best to preserve and improve skeletal health in the veteran population. In specific, their report is not meant to be a guideline. The role of guideline development is that of the VA guidelines committee, which will use this evidence synthesis in its deliberation.