# FUTURE RESEARCH

Our review suggests that additional and extensive research is urgently needed to better understand the risk factors, prevalence, and application of screening tests for male osteoporosis. While osteoporosis has been extensively evaluated in women, comparably little work has been done in men. As the largest integrated health care system in the U.S., serving a population that is more than 95% male and 80% over the age of 50, these issues are of particular concern and importance to the VA.

In particular, we have identified three areas of future research in male osteoporosis that we believe to be of critical importance to the VA:

1. Determine the scope of the problem within the veteran population. We did not find any veteran-specific data on the prevalence of osteoporosis or osteopenia in male veterans. Applying our own calculations based on NHANES III data, we estimate up to 400,000 veterans may have osteoporosis and 3 million may have osteopenia. However, as the NHANES cohort was a relatively healthy sample of the U.S. population, and as Veterans tend on average to have more comorbidity than non-Veterans, our calculations may underestimate the prevalence of osteoporotic disease in Veterans. Research that attempts to quantify the number of the Veterans at risk for osteoporotic disease, such as those that evaluate a representative veteran population, will help the VA better understand the burden of current and future osteoporotic disease. Cross-sectional studies of association will be helpful to better define which Veterans are most likely to have osteoporosis.
2. Further elucidate the test characteristics of promising screening tests. Based on limited evidence, we find the OST to be a promising screening test that could potentially be widely employed for male osteoporosis screening. An advantage to the OST is that is can be easily applied with existing data and could require minimal effort to program a CPRS clinical reminder using age and weight, which could trigger a patient specific request for a DXA scan. However, only three studies that evaluated the OST, of which only one in our analysis assessed a Veteran population. Additional research effort should be focused on testing the sensitivity, specificity, and positive predictive value of the OST in Veterans.
3. Determine the optimal screening regimen for male osteoporosis in Veterans. Ultimately, the goal of a male osteoporosis screening program will be to determine and implement a sensitive yet cost-effective screening strategy. Future clinical research efforts should focus on evaluating and comparing different screening strategies. In addition, computer modeling, including cost-effectiveness analysis, should be used to aid decision-making on optimal resource allocation. Avaliable evidence suggests that universal screening with cDXA based on age is unlikely to be cost-effective: strategies of targeted screening with cDXA based on other risk factors have not been evaluated.