# Evidence Table

Evidence Table 1 Diagnostic Test Studies

Columns 1–10: Article, Population, Characteristics, Sample Size, Study test & site, Reference test & site, QUADAS, Results

Author, Year, Region, Trial Name | Population | Characteristics | Male sample size | Study | | Reference | | QUADAS^*^ | Results
Author, Year, Region, Trial Name | Population | Characteristics | Male sample size | Test | Site | Test | Site | QUADAS^*^ | Results
Adler, 2001 27 US/Canada | Referred for DXA | NR, Veteran | 185 | Ultrasound BUA & QUI | Calcaneus | Central DXA | Spine, Femur | 3,3,1,1,1,1,1,1,1,3,3,1,1,3 | Central DXA T-score<−1.5 Heel T-score<0: Sens=0.89, Spec=0.40 Heel T-score<−0.5: Sens=0.79, Spec=0.48 Heel T-score<−1.0: Sens=0.65, Spec=0.75 Heel T-score<−1.5: Sens=0.49, Spec=0.84 Heel T-score<−2.0: Sens=0.30, Spec=0.94 Heel T-score<−2.5: Sens=0.07, Spec=0.98 Central DXA T-score<−2.0 Heel T-score<0: Sens=0.92, Spec=0.35 Heel T-score<−0.5: Sens=0.86, Spec=0.47 Heel T-score<−1.0: Sens=0.71, Spec=0.68 Heel T-score<−1.5: Sens=0.53, Spec=.079 Heel T-score<−2.0: Sens=0.30, Spec=0.89 Heel T-score<−2.5: Sens=0.06, Spec=0.97 Central DXA T-score<−2.5 Heel T-score<0: Sens=0.91, Spec=0.27 Heel T-score<−0.5: Sens=0.86, Spec=0.38 Heel T-score<−1.0: Sens=0.74, Spec=0.59 Heel T-score<−1.5: Sens=0.60, Spec=0.73 Heel T-score<−2.0: Sens=0.34, Spec=0.86 Heel T-score<−2.5: Sens=0.07, Spec=0.97
Adler, 2003 19 US/Canada | Pulmonary Clinic | Asian, Veteran | 107 | Ultrasound BUA, SOS & QUI; questionnaire | Calcaneus | Central DXA | Spine, Femur | 1,1,1,1,2,1,1,1,1,3,3,1,1,3 | Central DXA T-score<−2.0, Heel T-score<−1.5: Sens=0.41, Spec=0.77
Adler, 2003 35 US/Canada | Pulmonary & Rheumatology Clinic | Pulmonary & Rheumatology Clinic, Veteran | 181 | Questionnaire OST | NA | Central DXA | Spine, Femur | 1,1,1,1,1,1,1,1,1,3,3,1,1,1 | Central DXA T-score<−2.0 OSTA score<1: Sens=0.62, Spec=0.89 OSTA score<2: Sens=0.69, Spec=0.82 OSTA score<3: Sens=0.74, Spec=0.72 Central DXA T-score<−2.5 OSTA score<1: Sens=0.75, Spec=0.80 OSTA score<2: Sens=0.82, Spec=0.74 OSTA score<3: Sens=0.93, Spec=0.66
Cheng, 1997 95 Scandinavia | Elderly | NR | 205 | Peripheral bone density pDXA | Calcaneus | Fracture Occurrence | Multiple Sites | 2,1,1,1,2,1,1,1,1,3,3,1,1,1 | Determined that calcaneal BMD can be used as a predictor of fracture occurrence in 75–80 year old men.
De Laet, 1998 96 Western Europe | Elderly | NR | 2778 | Central DXA, Hiefy Risk using DCA | Femur, NA | Fracture Occurrence | NA | 1,1,1,1,1,1,1,1,1,3,3,1,1,1 | Evaluated a hip fracture risk equation which included age and femoral neck BMD and found that they were able to accurately predict hip fracture over an approximate four year period.
Donaldson, 1999 72 Western Europe | Elderly | NR | 817 | Ultrasound BUA | Calcaneus | Fracture Occurrence | NR | 1,1,3,1,2,3,1,1,1,3,3,1,1,2 | Found no significant difference between fixed or anatomic BUA values in men with or without a past fracture.
Gonnelli, 2005 68 Western Europe | Bone Clinic | NR | 407 | Ultrasound BUA & SOS; Central DXA | Spine, Femur, Calcaneus | Fracture Occurrence | Spine, Femur, Radius, Pelvis | 2,1,1,1,1,1,1,1,1,3,3,1,1,1 | Found that hip BMD (OR 3.4, 2.5–4.8) and QUS stiffness (OR 3.2, 2.3–4.5) had strong associations with fractures and that combining these two parameters resulted in an even stronger association (OR 6.1, 2.6–14.3).
Grampp, 2001 66 Western Europe | Referred for BMD | NR | 501 | Ultrasound QUS | Calcaneus | Central DXA | Spine, Femur | 2,1,1,1,1,1,1,1,1,3,3,1,1,1 | Insufficient statistics for sensitivity and specificity calculation
Gudmundsdottir, 2005 20 Scandinavia | Unselected | NR | 589 | Ultrasound BUA, SOS & SI | Calcaneus | Central DXA | Spine, Femur | 2,1,1,1,3,1,1,1,1,3,3,1,1,2 | Total hip DXA T-score<−2.5 QUS T-score<0: Sens=1.0, Spec=0.14 QUS T-score<−0.5: Sens=0.86, Spec=0.28 QUS T-score<−1.0: Sens=0.82, Spec=0.49 Femoral neck BMD T-score<=−2.5 QUS T-score<0: Sens=1.0, Spec=0.13 QUS T-score<−0.5: Sens=0.92, Spec=0.28 QUS T-score<−1.0: Sens=0.83, Spec=0.47
Kaptoge, 2004 17 Western Europe | Unselected | NR | 2653 | Simple Score Male Multivariate Model | Spine | Fracture Occurrence | Spine, Femur, Radius, Rib, Other | 1,1,1,1,1,1,1,1,1,3,3,1,1,1 | Found that the risk for prevalent vertebral fracture significantly increased with age (RR 1.3, 1.2–1.5), height loss (RR 1.1, 1.0–1.1), self-reported spine fractures (RR 5.1, 3.7–6.9), and weight (RR 0.9, 0.8–0.9).
Karlsson, 1996 14 Scandinavia | Unselected | NR | 33 | Central DXA; X-ray | Femur | Fracture Occurrence | Femur | 1,1,1,1,1,1,1,1,1,3,3,3,1,1 | Found a significant correlation between age and femoral shaft width (r=0.4), cervical width (r=0.4); no significant correlation was found between radiographic signs of osteoporosis and DXA hip values.
Kroger, 1999 97 Scandinavia, Western Europe | Referred – PCP | NR | 68 | Central DXA; Quantitative CT | Spine, Femur | Fracture Occurrence | Spine, Femur | 3,2,1,3,3,3,1,1,1,3,3,3,3,3 | Found that axial and peripheral quantitative CT performed comparably to DXA in spinal osteoporosis assessment.
Kung, 2005 63 Asia | Elderly | Asian | 776 | Ultrasound BUA; SOS & QUI; OSTA | Calcaneus NA | Central DXA | Spine, Femur | 2,1,1,1,1,1,1,1,1,3,3,1,1,3 | Femoral neck BMD T-score<=−2.5 OSTA score <=−1.0: Sens=0.71, Spec=0.68 QUI T-score<−1.2: Sens=0.76, Spec=0.72
Li-Yu, 2005 15 Asia | Unselected | Filipino | 132 | OSTA | NA | Central DXA | Femur | 2,1,1,1,1,1,1,2,1,3,1,1,3,3 | Femoral neck BMD T-score<=−2.5 OSTA score <−1.0: Sens=0.91, Spec=0.66
Lynn, 2005 65 Asia | Elderly | Asian | 2000 | Ultrasound QUI; MOST | NA | Central DXA | Spine, Femur | 2,1,1,1,3,1,1,1,1,3,3,1,1,3 | Central BMD T-score <−2.5 MOST score > 3: Sens=0.94, Spec=0.46
Melton, 2005 98 US/Canada | Unselected | NR | 348 | Bone Structural Parameters | Femur | Central DXA, Fracture Occurrence | Femur | 1,1,1,1,1,1,2,1,1,3,3,1,1,2 | Found that the best predictors of osteoporotic fractures in a multivariate in men included age (OR per 10 years, 1.5; 1.1–2.1), femoral neck section modulus (OR, 1.6; 1.1–2.5), and intertrochanteric buckling ratio (OR 1.6; 1.3–2.0).
Montagnani, 2001 67 Western Europe | Unselected | NR | 182 | Central DXA; Ultrasound | Spine, Femur, Finger | Fracture Occurrence | NR | 1,2,1,1,1,1,1,1,1,3,3,1,1,1 | Evaluated usefulness of ultrasound of the phalanx and in regression analysis found that only one parameter, bone transmission time (BTT), was comparable to DXA parameters in determining fracture risk.
Mulleman, 2002 [#1274] Western Europe | Referral | NR | 102 | Ultrasound BUA, SOS & SI | Calcaneus | Central DXA, Fracture Occurrence | Spine, Femur | 2,1,3,1,1,1,1,1,1,3,3,1,1,1 | Quantitative ultrasound (QUS) is associated with low-trauma fracture (OR 2.3 and 2.1 for SOS and SI respectively), although sensitivity is less than when results are compared with BMD at the lumbar spine (OR 2.8) and hip (OR=3.4) with an area under the curve in ROC analysis for BMD of Lumbar spine = 0.80 and BUA 0.69 (P<0.05). Lumbar spine DXA T-score<=−2.5 QUS T-score <=−2.5: Sens=0.56, Spec=0.84; Femoral neck DXA T-score<=−2.5 QUS T-score <=−2.5: Sens=0.64, Spec=0.74; Hip DXA T-score<=−2.5 QUS T-score <=−2.5: Sens=0.41, Spec=0.93; Stiffness index DXA T-score <=−2.5 QUS T-score <=−2.5: Sens=0.60, Spec=0.78;
Odvina, 1988 99 US/Canada | Referral for Osteoporosis | NR, Veteran | 38 | Quantitative CT | Spine | Fracture Occurrence | | 2,1,1,1,1,1,1,1,1,3,3,1,1,1 | Employed trabecular vertebral body density by CT to determine fracture threshold in men and women. Although fracture threshold was not well defined in men, the values obtained by different methods were in close agreement to those noted in women. Fracture threshold was higher in men than women (123 ±7 vs. 101 ±2 mg/cm^3^, p<0.001).
Robinson, 1987 100 Australia | Referred by Hospital Staff | NR | 31 | Linear Photon Absorptiometry | Spine, Radius | Quantitative CT, Fracture Occurrence | Spine | 2,2,1,1,3,3,1,1,1,3,3,1,1,3 | Found that men with vertebral fractures has significantly lower mean forearm osteodensitometry and spinal mineral content than age matched men without a history of fractures (16 point difference in “arbitrary units,” p<0.02; 65 mg equivalent K^2^HPO_4_/cm^3^, p<0.0025, respectively).
Rothenberg, 2004 70 US/Canada | Unselected | NR | 301 | Ultrasound Bone Density | Calcaneus | Fracture Occurrence | Spine, Femur, Radius, Shoulder, Ribs | 1,1,3,1,1,1,1,1,1,3,3,1,1,1 | Estimated that the Hologic T-score of −0.2 corresponds to a BMD of 0.57 gm/cm^2^ which corresponds to an increase in relative risk of fracture of 1.4.
Shin, 2005 101 Asia | Unselected, Elderly | Asian | 1225 | Ultrasound BUA, SOS & Stiffness | Calcaneus | Peripheral bone density pDXA | Radius, Calcaneus | 2,1,1,1,1,1,1,1,1,3,3,1,1,2 | Found that correlations between QUS and BMD were 0.41 to 0.73 in men, with peak mean values for QUS occurring in men aged 20–29 years old.
Stewart, 1995 73 Western Europe | Unselected | NR | 247 | Ultrasound BUA; Central DXA | Spine, Femur, Calcaneus | Fracture Occurrence | Spine | 1,3,1,1,1,1,1,1,1,3,3,1,1,1 | No statistically significant relationship between BUA or DXA at any site and fractures in men in bivariate analyses.
Travers-Gustafson, 1995 74 US/Canada | Elderly | NR | 529 | Peripheral Bone Density other; AVU | Radius, Patella | Fracture Occurrence | NR | 1,1,3,1,1,1,1,1,1,3,3,1,1,1 | Apparent velocity of ultrasound (AVU) is highly associated with low trauma fractures in both women (OR 1.46, 95% CI=1.18,1.81) and men (OR 1.69, 95% CI=1.24,2.32).
Varenna, 2005 69 Western Europe | Unselected | NR | 4832 | Ultrasound BUA, SOS, & SI | Calcaneus | Fracture Occurrence | Femur, Non-spinal | 1,1,3,1,1,1,1,1,1,3,3,1,1,1 | Found that each SD reduction in QUS measurement resulted in a significant approximate 2X increase in risk of hip fracture, independent of age and other clinical variables, consistent with findings found in elderly women.
Welch, 2004 71 Western Europe | Unselected | NR | 6860 | Ultrasound BUA | Calcaneus | Fracture Occurrence | Spine, Femur, Radius | 1,1,3,1,1,1,1,1,1,3,3,1,1,1 | Found differences sex differences in relationship between osteoporosis risk factors and BUA. Age, weight, and height explained 27% of the variance of BUA in women, but only 3% in men.
Bauer, 2006 75 US/Canada | Elderly | NR | 5608 | Ultrasound BUA, Central DXA | Femur, Calcaneus | Fracture Occurrence | Femur | 1,1,1,1,1,1,1,3,3,1,1,1,1,3 | Each SD decrease in calcaneal ultrasound BUA was associated with an increased rate of hip (RH= 1.97, CI: 1.32, 3.54) and non-spine (RH=1.65, CI: 1.38,1.96) fracture. Ultrasound predicted hip and non-spine fractures almost as well as femoral BMD, and the combination of these tests was not better than either test alone.

* QUADAS 1=Yes, 2=No, 3=Unclear; Order is: Spectrum representativeness, Selection criteria, Reference standard, Time period, Verification bias, Use of same reference test, Independence, Detail of index test, Details of reference test, Blinding #1, Blinding #2, Usefulness in practice, Intermediate results, Withdrawls

NR=Not Reported

SOS=Speed of sound

SI=Stiffness Index

BUA=Broad-band ultrasound attenuation

OST=Osteoporosis Screening Tool

OSTA=Osteoporosis Screening Tool for Asians

QUI=Quantitative Ultrasound Index

BMD=Bone Mass Density

MOST=Male Osteoporosis Screening Tool

DXA=Dual energy x-ray absorptiometry

QUS=Quantitative Ultrasound

AVU=Apparent velocity of ultrasound