# Data Collection Forms

VA-EPC Male/OP Project Screener

VA Male OP Project-Detailed Review Form - Diagnostic Studies

VA Male OP QUADAS Quality Review Form

VA Male OP Project- RISK FACTOR STUDIES

VA Male OP Project-Detailed Review Form - RISK FACTOR STUDIES

VA Male OP Project - RISK FACTOR STUDIES, Quality Measurement