# REFERENCES

1 Friedman DS, O'Colmain BJ, Munoz B, et al. Prevalence of age-related macular degeneration in the United States. Archives of Ophthalmology. Apr. 2004;122(4):564-572. [pmid: 15078675].
2 Augood C, Chakravarthy U, Young I, et al. Oily fish consumption, dietary docosahexaenoic acid and eicosapentaenoic acid intakes, and associations with neovascular age-related macular degeneration. American Journal of Clinical Nutrition. Aug. 2008;88(2):398-406. [pmid: 18689376].
3 Flood V, Smith W, Wang JJ, Manzi F, Webb K, Mitchell P. Dietary antioxidant intake and incidence of early age-related maculopathy: the Blue Mountains Eye Study. Ophthalmology. Dec. 2002;109(12):2272-2278. [pmid: 12466170].
4 Mares JA, Voland RP, Sondel SA, et al. Healthy lifestyles related to subsequent prevalence of age-related macular degeneration. Archives of Ophthalmology. Apr. 2011;129(4):470-480. [pmid: 21149749].
5 Mares-Perlman JA, Klein R, Klein BE, et al. Association of zinc and antioxidant nutrients with age-related maculopathy. Archives of Ophthalmology. Aug. 1996;114(8):991-997. [pmid: 8694736].
6 Moeller SM, Parekh N, Tinker L, et al. Associations between intermediate age-related macular degeneration and lutein and zeaxanthin in the Carotenoids in Age-related Eye Disease Study (CAREDS): ancillary study of the Women's Health Initiative. Archives of Ophthalmology. Aug. 2006;124(8):1151-1162. [pmid: 16908818].
7 VandenLangenberg GM, Mares-Perlman JA, Klein R, Klein BE, Brady WE, Palta M. Associations between antioxidant and zinc intake and the 5-year incidence of early age-related maculopathy in the Beaver Dam Eye Study. American Journal of Epidemiology. Jul. 15. 1998;148(2):204-214. [pmid: 9676703].
8 Higgins JPT, Altman DG, editors. Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. 2008; Version 5.0.1 [updated September 2008]. The Cochrane Collaboration. 2008. Available from www.cochrane-handbook.org.
9 Guyatt G, Oxman AD, Akl EA, et al. GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. Journal of Clinical Epidemiology. Apr. 2011;64(4):383-394. [pmid: 21195583].
10 Age-Related Eye Disease Study Research Group. A randomized, placebo-controlled, clinical trial of high-dose supplementation with vitamins C and E, beta carotene, and zinc for age-related macular degeneration and vision loss: AREDS report no. 8. Archives of Ophthalmology. Oct. 2001;119(10):1417-1436. [pmid: 11594942].
11 Newsome DA, Swartz M, Leone NC, Elston RC, Miller E. Oral zinc in macular degeneration. Archives of Ophthalmology. Feb. 1988;106(2):192-198. [pmid: 3277606].
12 Richer S, Stiles W, Statkute L, et al. Double-masked, placebo-controlled, randomized trial of lutein and antioxidant supplementation in the intervention of atrophic age-related macular degeneration: the Veterans LAST study (Lutein Antioxidant Supplementation Trial). Optometry. Apr. 2004;75(4):216-230. [pmid: 15117055].
13 Stur M, Tittl M, Reitner A, Meisinger V. Oral zinc and the second eye in age-related macular degeneration. Investigative Ophthalmology & Visual Science. Jun. 1996;37(7):1225-1235. [pmid: 8641826].
14 Newsome DA. A randomized, prospective, placebo-controlled clinical trial of a novel zinc-monocysteine compound in age-related macular degeneration. Current Eye Research. Jul. 2008;33(7):591-598. [pmid: 18600492].
15 Richer S. Multicenter ophthalmic and nutritional age-related macular degeneration study-part 2: antioxidant intervention and conclusions. Journal of the American Optometric Association. Jan. 1996;67(1):30-49. [pmid: 8825017].
16 Feher J, Kovacs B, Kovacs I, Schveoller M, Papale A, Balacco Gabrieli C. Improvement of visual functions and fundus alterations in early age-related macular degeneration treated with a combination of acetyl-L-carnitine, n-3 fatty acids, and coenzyme Q10. Ophthalmologica. May-Jun. 2005;219(3):154-166. [pmid: 15947501].
17 Age-Related Eye Disease Study 2 Investigators. Age-Related Eye Disease Study 2 (AREDS2): A Multi-Center, Randomized Trial of Lutein, Zeaxanthin and Omega-3 Long-Chain Polyunsaturated Fatty Acids (Docosahexaenoic Acid [DHA] and Eicosapentaenoic Acid [EPA]) in Age-Related Macular Degeneration. ClinicalTrials.gov identifier: NCT00345176. (Ongoing study).
18 Evans J. Antioxidant supplements to prevent or slow down the progression of AMD: a systematic review and meta-analysis. Eye. Jun. 2008;22(6):751-760. [pmid: 18425071].
19 Miller ER 3rd, Pastor-Barriuso R, Dalal D, et al. Meta-analysis: high-dosage vitamin E supplementation may increase all-cause mortality. Annals of Internal Medicine. Jan. 4. 2005;142(1):37-46. [pmid: 15537682].
20 Gallicchio L, Boyd K, Matanoski G, et al. Carotenoids and the risk of developing lung cancer: a systematic review. American Journal of Clinical Nutrition. Aug. 2008;88(2):372-383. [pmid: 18689373].
21 Tanvetyanon T, Bepler G. Beta-carotene in multivitamins and the possible risk of lung cancer among smokers versus former smokers: a meta-analysis and evaluation of national brands. Cancer. Jul. 1. 2008;113(1):150-157. [pmid: 18429004].
22 Bjelakovic G, Nagorni A, Nikolova D, Simonetti RG, Bjelakovic M, Gluud C. Meta-analysis: antioxidant supplements for primary and secondary prevention of colorectal adenoma. Alimentary Pharmacology & Therapeutics. Jul. 15. 2006;24(2):281-291. [pmid: 16842454].
23 Bjelakovic G, Nikolova D, Simonetti RG, Gluud C. Systematic review: primary and secondary prevention of gastrointestinal cancers with antioxidant supplements. Alimentary Pharmacology & Therapeutics. Sep. 15. 2008;28(6):689-703. [pmid: 19145725].
24 Jiang L, Yang Kh, Tian Jh, et al. Efficacy of antioxidant vitamins and selenium supplement in prostate cancer prevention: a meta-analysis of randomized controlled trials. Nutrition & Cancer. Aug. 2010;62(6):719-727. [pmid: 20661819].
25 Virtamo J, Pietinen P, Huttunen JK, et al. Incidence of cancer and mortality following alpha-tocopherol and beta-carotene supplementation: a postintervention follow-up. JAMA. Jul. 23. 2003;290(4):476-485. [pmid: 12876090].
26 Goodman GE, Thornquist MD, Balmes J, et al. The Beta-Carotene and Retinol Efficacy Trial: Incidence of lung cancer and cardiovascular disease mortality during 6-year follow-up after stopping Î²-carotene and retinol supplements. Journal of the National Cancer Institute. 2004;96(23):1743-1750. [pmid: 15572756].
27 The effect of vitamin E beta carotene on the incidence of lung cancer and other cancers in male smokers. The Alpha-Tocopherol, Beta Carotene Cancer Prevention Study Group. New England Journal of Medicine. Apr. 14. 1994;330(15):1029-1035. [pmid: 8127329].
28 Omenn GS, Goodman GE, Thornquist MD, et al. Effects of a combination of beta carotene and vitamin A on lung cancer and cardiovascular disease. New England Journal of Medicine. May. 2. 1996;334(18):1150-1155. [pmid: 8602180].
29 Hennekens CH, Buring JE, Manson JE, et al. Lack of effect of long-term supplementation with beta carotene on the incidence of malignant neoplasms and cardiovascular disease. New England Journal of Medicine. May. 2. 1996;334(18):1145-1149. [pmid: 8602179].
30 Lee IM, Cook NR, Manson JE, Buring JE, Hennekens CH. Beta-carotene supplementation and incidence of cancer and cardiovascular disease: the Women's Health Study. Journal of the National Cancer Institute. Dec. 15. 1999;91(24):2102-2106. [pmid: 10601381].
31 Lippman SM, Klein EA, Goodman PJ, et al. Effect of selenium and vitamin E on risk of prostate cancer and other cancers: the Selenium and Vitamin E Cancer Prevention Trial (SELECT). JAMA. Jan. 7. 2009;301(1):39-51. [pmid: 19066370].
32 Klein EA, Thompson IM Jr, Tangen CM, et al. Vitamin E and the risk of prostate cancer: the Selenium and Vitamin E Cancer Prevention Trial (SELECT). JAMA. Oct. 12. 2011;306(14):1549-1556. [pmid: 21990298].
33 Leppala JM, Virtamo J, Fogelholm R, et al. Controlled trial of alpha-tocopherol and beta-carotene supplements on stroke incidence and mortality in male smokers. Arteriosclerosis, Thrombosis & Vascular Biology. Jan. 2000;20(1):230-235.
34 Marchioli R, Levantesi G, Macchia A, et al. Vitamin E increases the risk of developing heart failure after myocardial infarction: Results from the GISSI-Prevenzione trial. Journal of Cardiovascular Medicine. May. 2006;7(5):347-350. [pmid: 16645413].
35 Lonn E, Bosch J, Yusuf S, et al. Effects of long-term vitamin E supplementation on cardiovascular events and cancer: a randomized controlled trial. JAMA. Mar. 16. 2005;293(11):1338-1347. [pmid: 15769967].
36 Burr ML, Ashfield-Watt PAL, Dunstan FDJ, et al. Lack of benefit of dietary advice to men with angina: results of a controlled trial. European Journal of Clinical Nutrition. Feb. 2003;57(2):193-200. [pmid: 12571649].
37 Bairati I, Roy L, Meyer F. Double-blind, randomized, controlled trial of fish oil supplements in prevention of recurrence of stenosis after coronary angioplasty. Circulation. Mar. 1992;85(3):950-956. [pmid: 1537131].
38 Leaf A, Jorgensen MB, Jacobs AK, et al. Do fish oils prevent restenosis after coronary angioplasty?. Circulation. Nov. 1994;90(5):2248-2257. [pmid: 7955181].
39 Kaul U, Sanghvi S, Bahl VK, Dev V, Wasir HS. Fish oil supplements for prevention of restenosis after coronary angioplasty. International Journal of Cardiology. Apr. 1992;35(1):87-93. [pmid: 1563884].
40 Kowey PR, Reiffel JA, Ellenbogen KA, Naccarelli GV, Pratt CM. Efficacy and safety of prescription omega-3 fatty acids for the prevention of recurrent symptomatic atrial fibrillation: a randomized controlled trial. JAMA. Dec. 1. 2010;304(21):2363-2372. [pmid: 21078810].
41 Graat JM, Schouten EG, Kok FJ. Effect of daily vitamin E and multivitamin-mineral supplementation on acute respiratory tract infections in elderly persons: a randomized controlled trial. JAMA. Aug. 14. 2002;288(6):715-721. [pmid: 12169075].
42 Johnson AR, Munoz A, Gottlieb JL, Jarrard DF. High dose zinc increases hospital admissions due to genitourinary complications. Journal of Urology. 2007;177:639-643. [pmid: 17222649].
43 Tardif JC, Cote G, Lesperance J, et al. Probucol and multivitamins in the prevention of restenosis after coronary angioplasty. Multivitamins and Probucol Study Group. New England Journal of Medicine. Aug. 7. 1997;337(6):365-372. [pmid: 9241125].
44 Shao A, Hathcock JN. Risk assessment for the carotenoids lutein and lycopene. Regulatory Toxicology & Pharmacology. Aug. 2006;45(3):289-298. [pmid: 16814439].
45 Granado F, Olmedilla B, Gil-Martinez E, Blanco I. Lutein ester in serum after lutein supplementation in human subjects. British Journal of Nutrition. Nov. 1998;80(5):445-449. [pmid: 9924266].
46 Olmedilla B, Granado F, Southon S, et al. A European multicentre, placebo-controlled supplementation study with alpha-tocopherol, carotene-rich palm oil, lutein or lycopene: analysis of serum responses. Clinical Science. Apr. 2002;102(4):447-456. [pmid: 11914107].
47 Leng GC, Lee AJ, Fowkes FG, et al. Randomized controlled trial of gamma-linolenic acid and eicosapentaenoic acid in peripheral arterial disease. Clinical Nutrition. Dec. 1998;17(6):265-271. [pmid: 10205349].
48 Holz FG, Spaide RF, editors. Medical Retina - Essentials in Ophthalmology. Berlin Heidelberg New York. Springer. 2007.