# METHODS

## TOPIC DEVELOPMENT

The review was commissioned by the Department of Veterans Affairs' Evidence-based Synthesis Program. We conferred with VA and non-VA experts to select the patients and subgroups, interventions, outcomes, and setting addressed in the review. We addressed the following key questions in our review of the literature:

1. In patients with age-related macular degeneration, do nutritional supplements containing carotenoids, antioxidants, or omega-3 fatty acids alone or in combination prevent functional visual loss?
2. In adult populations, what are the harms of carotenoid, antioxidant, and omega-3 fatty acid supplementation?

The criteria for patient population, treatment and comparator interventions, outcomes of interest, and patient care setting are outlined below:

Patients: Adults with nonexudative age-related macular degeneration
Interventions: | Carotenoids – zeaxanthin, lutein, beta-carotene Antioxidants – zinc, vitamin E, vitamin C Omega-3 fatty acids – alpha linolenic acid (C18:3n-3), docosahexaenoic acid (DHA; C22:6n-3), eicosapentaenoic acid (EPA; C20:5n-3)
Comparators: Placebo
Outcomes: Vision loss, defined as visual impairment in the best eye as follows:; - ≤ 20/60 by Snellen acuity; or ≤ 6/18 metric acuity; or doubling of the visual angle (e.g. 20/50 to 20/100); or ≥ three lines of loss; or ≥ 15 letters lost (ETDRS chart); or, progression to advanced disease (either central geographic atrophy or wet macular degeneration). Note: A 3-line change in visual acuity (i.e. +/-15 letters) using the ETDRS chart is equivalent to a doubling of the visual angle.; - Other outcomes: quality of life and functional status
Setting: Outpatient

Figure 1 illustrates the analytic framework that guided our review and synthesis.

Figure 1 Analytic Framework

## SEARCH STRATEGY

We conducted a search in Medline^®^ Embase, Scopus, Conference Papers Index, and the Cochrane Library (Cochrane Database of Systematic Reviews; Database of Abstracts of Reviews of Effects; Cochrane Central Register of Controlled Trials) from 1947 or database inception through February 2011. Appendix A provides the search strategy in detail. We obtained additional articles from systematic reviews, reference lists of pertinent studies, reviews, editorials, and by consulting experts. All citations were imported into an electronic database (EndNote X1).

## STUDY SELECTION

Four reviewers assessed for relevance the abstracts of citations identified from literature searches. Full-text articles of potentially relevant abstracts were retrieved for further review. Each article retrieved was independently reviewed by two authors using the eligibility criteria shown in Appendix B.

Eligible articles had English-language abstracts and provided primary data relevant to the key questions. Eligibility criteria varied depending on the question of interest, as described below.

To evaluate the efficacy of oral supplements, we considered prospective, controlled clinical trials comparing the effects of carotenoids, antioxidants, or omega-3 fatty acids (alone or in combination) with usual care or placebo on clinically significant vision loss, quality of life, or functional status among adults with age-related macular degeneration. We defined clinically important vision loss as any one of the following based on input from our Technical Expert Panel: ≤20/60 by Snellen acuity; or ≤6/18 metric acuity; or doubling of the visual angle (e.g. 20/50 to 20/100); or ≥ three lines of loss; or ≥15 letters lost; or progression to advanced disease (either central geographic atrophy or wet macular degeneration). We did not limit RCTs by sample size or duration of treatment.

We used a similar approach to evaluate the adverse effects of these oral supplements, but we also included studies of adults without AMD because the potential harms of oral supplements are not specific to those with AMD. Since nutritional supplements for AMD are intended for use over long periods of time and because clinically important harms not detected by AMD studies are unlikely to be evident in very small studies, we included only those studies with at least 24 weeks of follow-up and a sample size of 100 or more subjects (Appendix B).

## DATA ABSTRACTION

From each study, we abstracted the following: study setting; number of subjects; population characteristics (including sex, age, race/ethnicity); treatment type, dosage and duration; type of control used; visual outcome results; proportion of subjects who progressed to severe AMD; quality of life and functional outcome results; adverse effects or treatments; and funding source.

## STUDY QUALITY

Two reviewers independently assessed the quality of each AMD trial using a tool developed by the Cochrane Collaboration (Appendix C).8 This tool asks the following questions about the methodologic characteristics of each study to guide assessment of the risk of bias:

- Was the allocation sequence adequately generated?
- Was allocation adequately concealed?
- Blinding of participants, personnel and outcome assessors: Was knowledge of the allocated intervention adequately prevented during the study?
- Were incomplete outcome data adequately addressed?
- Are reports of the study free of suggestion of selective outcome reporting?
- Was the study apparently free of other problems that could put it at a high risk of bias? (We assessed whether or not there were extreme baseline differences between groups.)

Disagreements were resolved through discussion. Each study was then given an overall summary assessment of low, high, or unclear risk of bias. The risk of bias within a given study can vary according to outcome. For instance, the risk of bias associated with lack of blinding might be low for mortality outcomes, but high for more subjective outcomes such as quality of life or symptom scores.

## RATING THE BODY OF EVIDENCE

We assessed the overall body of evidence for each outcome by considering the consistency, coherence, and applicability across studies, as well as the internal validity of individual studies, using a method developed by the Grades of Recommendation, Assessment, Development, and Evaluation (GRADE) Working Group.9

## DATA SYNTHESIS

We critically analyzed the strength of the evidence regarding both efficacy and adverse treatment effects, and compiled a qualitative synthesis of findings. We could not conduct a quantitative synthesis because the outcome measures, treatments, and populations differed substantially across trials.

## PEER REVIEW

A draft version of this report was sent to the Technical Expert Panel and additional peer reviewers. We revised the report based on peer review feedback (Appendix D).