# INTRODUCTION

Age-related macular degeneration (AMD) is the leading cause of irreversible vision loss in the developed world. In 2004, AMD affected 1.75 million persons in the United States, a number which is expected to rise to nearly 3 million by 2020 due to the aging of the population.1 AMD is characterized by the appearance of involutional changes (e.g. drusen) in the structure of the central retinal pigment epithelium (RPE) leading to the loss of normal central (macular) vision. AMD can be categorized as dry (non-exudative) or wet (exudative). Dry AMD represents the great majority of AMD patients (90%) and may lead to slow visual loss over many decades, with the most severe cases developing geographic atrophy and profound loss of central vision. Dry AMD can progress to wet AMD with the development of neovascularization beneath the diseased RPE leading to hemorrhage, scarring, and the devastating loss of macular vision over a period of months.

By convention, there are four categories which describe the severity of macular degeneration. Category 1 are those patients essentially free of age-related macular abnormalities, with a total drusen area less than five small drusen (63 μm), and visual acuity of 20/32 or better in both eyes. Category 2 patients have mild or borderline, age-related macular features (multiple small drusen, single or nonextensive intermediate drusen (63-124 μm), pigment abnormalities, or any combination of these) in one or both eyes, and visual acuity of 20/32 or better in both eyes. Category 3 patients require the absence of advanced AMD in both eyes and at least one eye with visual acuity of 20/32 or better with at least one large drusen (125 μm), extensive (as measured by drusen area) intermediate drusen, or geographic atrophy (GA) that does not involve the center of the macula, or any combination of these. Category 4 patients have visual acuity of 20/32 or better and no advanced AMD in one eye, with the fellow eye having either lesions of advanced AMD, or visual acuity less than 20/32 with AMD abnormalities sufficient to explain reduced visual acuity as determined by examination of photographs. “Advanced AMD” is defined as having GA involving the center of the macula or features of choroidal neovascularization.

Multiple prospective cohort studies including the Beaver Dam Eye Study, the Blue Mountains Eye Study, and the Carotenoids and Age-related Eye Disease Study (CAREDS), have found diets higher in zinc, vitamin C, vitamin E and carotenoids are associated with a lower risk of AMD progression.2-7 These observational studies, although limited by unmeasured confounding and potential recall bias, provided the rationale for controlled trials evaluating the efficacy of nutritional supplements in reducing the progression of AMD.

Our report focuses on the evidence documenting the potential benefits and harms of certain dietary supplements in patients with AMD. Recommendations to the Department of Veterans Affairs with regard to these supplements will have important implications to that patient population as well as to older U.S. adults. We conducted a systematic review of published literature to address the following key questions:

1. In patients with age-related macular degeneration, do nutritional supplements containing carotenoids, antioxidants, or omega-3 fatty acids alone or in combination prevent functional visual loss?
2. In adult populations, what are the harms of carotenoid, antioxidant, and omega-3 fatty acid supplementation?