# DISCUSSION

We conducted a systematic review of the benefits and harms of nutritional supplements for treatment of AMD. We found good evidence mainly from one large RCT that supplementation with carotenoids and antioxidants decreased the risk of functional vision loss among patients with Category 3 or 4 AMD. One smaller RCT also found zinc supplementation may decrease the risk of clinically significant visual loss among patients with Category 3 or 4 AMD, but six other RCTs found no clinically significant benefit from nutritional supplements in AMD patients. The effects of carotenoids or omega-3-fatty acids alone have not been well-studied.

It is likely that the discrepant findings reflect, at least in part, the size, length of follow-up, and patient characteristics in these six studies not finding benefit. These studies all included fewer than 200 patients each, were conducted over a relatively short time frame, and included large proportions of patients with mild AMD.

We also found evidence of significant potential harm from some nutritional supplements. Carotenoids such as beta-carotene have been associated with an estimated 24 percent increased risk of lung cancer among smokers. Similar to the studies of potential benefits, the evidence for harms is driven primarily by two large trials, ATBC and CARET. The release of the results regarding beta-carotene and lung cancer risk from ATBC in 1994^27^ and CARET in 1996^28^ caused an amendment to be made to the ongoing AREDS study, in which smokers were offered a chance to change their randomization of treatment supplements category to one which included either zinc alone or placebo. This concern also has been addressed in the subsequent AREDS II study, now underway, which is discussed below under Future Studies.48

Higher doses of vitamin E (>400 IU per day) have been associated with an estimated four percent increase in mortality; a 13 to 17 percent increase in risk of prostate cancer; and a 13 to 50 percent increase in risk of congestive heart failure among those with existing CVD risk factors such as left ventricular dysfunction, diabetes mellitus, recent myocardial infarction, or renal insufficiency.

Whether the balance of benefits and harms favors supplementation in AMD patients likely depends on the population being considered. There is strong evidence for benefit in patients with more advanced AMD; and in these patients, the very small risk of harm is likely to be outweighed by the potential benefit. Using the AREDS data, one can calculate the number needed to treat with supplements to prevent one patient from developing clinically significant visual loss, as 33 over five years. In a population of patients with comorbid cardiovascular disease, 256 would need to be treated with supplements (which include vitamin E) to cause one excess death.19

The role of nutritional supplementation in patients with mild AMD is unclear. The natural history of mild AMD is one of slow progression. Among 1,117 participants with Category 1 AMD at baseline in the AREDS study, only five (0.45%) participants developed advanced AMD during 6.3 mean years of follow-up. Among 1,063 subjects with Category 2 AMD at baseline, only 13 (1.2%) subjects had significant vision loss related to AMD, and 28 (2.6%) participants progressed to Category 3 or 4.^10^ There was no detectable effect on vision loss in any of the treatment arms among these subjects, given the very slow rate of disease progression in mild AMD. It is unclear, however, whether the rate of progression from mild to advanced AMD increases with age. It is possible that nutritional supplementation for mild AMD may yield more detectable benefit to those over age 85 compared with younger individuals. These aged individuals make up the fastest growing demographic in the United States. The natural progression of AMD in this age group warrants further study.

Since AMD patients are likely to be older and have additional medical comorbidities, many would be at risk for some of the potential harms associated with supplementation. Because of the very slow rate of disease progression in patients with mild AMD, the lack of evidence of benefit in these patients and the potential for harm – especially amongst those with baseline medical comorbidities – the current literature does not support widespread use of these supplements for mild AMD. The balance of benefits and harms in patients with Category 3 or 4 AMD and limited life expectancy is unclear. Because the benefits of nutritional supplements do take several years to accrue, it is unclear that their use in patients with limited life expectancy is indicated.

Our findings concur with and add to the findings of similar reviews. A recent Cochrane collaborative review found evidence for modest benefit of antioxidant, vitamin and mineral supplementation reducing the progression of AMD in people with moderate to severe signs of the disease, and no evidence that subjects with early signs of the disease show a treatment benefit.18 Our findings add to prior reviews in that we looked at a broader group of studies to examine the potential harms of supplements because the potential risks are not limited to only those with AMD, making studies including all older adults relevant to the question of harms.

## FUTURE STUDIES

Based on the progression observed in AREDS among subjects with Category 2 AMD, we estimate a study enrolling 17,000 subjects followed over five years would be needed to detect a clinically significant difference in visual loss between subjects treated with antioxidants + zinc versus a placebo. Such a study is unlikely to be funded and completed in the near future. The natural history of AMD is a very slow and lengthy progression from retinal evidence of disease to functional vision loss. Not all patients with evidence of retinal disease have vision impairment that interferes with functional status. In other words, subtle changes in retinal function due to AMD may cause visual disability that is not well reflected on the basis of visual acuity measurements alone. Well-validated intermediate markers of functional vision loss would be useful. Well-designed prospective cohort studies of patients with mild AMD could elucidate the types of intermediate findings that could accurately predict future clinically significant vision loss. In addition, studies would need to confirm that these findings are consistent when measured across large groups of patients.

Given the relative lack of information about the effects of xanthophylls, carotenoids, and omega-3 fatty acids, future trials should be considered to assess the effects of these supplements in AMD patients. The results of the ongoing AREDS II trial should help to address the current gaps in evidence about the effects of the xanthophyll and omega-3-fatty acids. In addition, the AREDS II trial interventions will include four variations of the original AREDS formula for randomization. However, smokers in the study will be randomized to only groups 2 or 3 since neither of these two groups’ supplements includes beta-carotene. The only variation between these two groups is the high or low Zinc content. This comprises a “smokers” subset of AREDS II.48

Previous and current studies, including the ongoing AREDS II trial, have focused on functional vision loss and AMD progression as the principal outcomes of interest. The large majority of patients with AMD, however, may suffer from more subtle visual disabilities that may, nevertheless, profoundly alter their visual functioning, such as losing their ability to safely operate a motor vehicle. It is important to emphasize that these patients, while visually impaired, may still record less than clinically significant visual loss as measured by visual acuity. Evidence is lacking as to whether quality of life outcomes and activities of daily living benefit from treatment, and further study of these outcome measures is warranted.

## CONCLUSIONS

Evidence of benefit from supplementation with carotenoids and antioxidants on functional vision loss in patients with AMD is based mainly on the results of one large trial. The observed benefit occurred only among subjects with Category 3 or 4 AMD. There is evidence for a low risk of harm from some nutritional supplements at high doses. As with any clinical intervention, the balance of benefits and harms regarding supplementation in AMD patients depends upon the population being considered. Given that AMD patients are older and have additional medical comorbidities, many would be at risk for some of the potential harms associated with supplementation. The precautionary principle should be observed while further evidence evolves. Table 2 summarizes the evidence regarding the benefits and harms of oral supplements for AMD.

Table 2 Summary of the evidence on the effects of nutritional supplements for age-related macular degeneration

Outcome | Treatment | Population | Effect^*^ | GRADE Classification^†^ | Comment
Functional vision loss | Carotenoids | Early AMD | (∼) | Low | Single study (N=90) found a small increase in visual acuity after 12 months, but the improvement was not clinically significant (i.e. <15 letters).12
Functional vision loss | Antioxidants^‡^ | Categories 3-4 AMD | (+) | Moderate | Evidence of benefit from 1 large multicenter trial10 and one smaller trial.11 4 small trials found neutral effects on functional vision loss.12-15
Functional vision loss | Antioxidants | Category 2 AMD | (∼) | Low | No evidence of benefit after 7 years of treatment in 1 large multicenter trial that included 1,063 Category 2 subjects.10
Functional vision loss | Omega-3 fatty acids | Early AMD (94% in Categories 1- 2) | (∼) | Very Low | One study found evidence of slowed visual acuity loss but not to a clinically significant degree. Very few subjects in this study (6.4%) had Categories 3-4 AMD.16
Quality of life | Carotenoids | AMD | (∼) | Low | No significant findings on night driving in one study (N=90).12
Quality of life | Antioxidants | N/A | (0) | N/A | No evidence.
Quality of life | Omega-3 fatty acids | N/A | (0) | N/A | No evidence.
Mortality | Beta-carotene | Smokers | (−) | Moderate | High-dose beta-carotene (20 to 30 mg/day) was linked with increased mortality in 2 large trials in smokers and asbestos workers.25, 26
Mortality | Vitamin E | General population | (−) | High | High-dose vitamin E (>=400 IU/day) was associated with a slight increase in mortality in a meta-analysis of 11 trials.19
Lung cancer | Beta-carotene | Smokers | (−) | Moderate | High-dose beta-carotene (20 to 30 mg/day) was linked with increased lung cancer incidence among smokers in a meta-analysis of 4 large trials.21 No increase in lung cancer was observed among former and non-smokers.
Prostate cancer | Vitamin E | General population | (−) | Low | High-dose vitamin E (400 IU/day) was associated with an increase in prostate cancer in one study.31
Gastrointestinal cancers | Antioxidants | General population | (∼) | High | Supplements had no effect on incidence of gastrointestinal cancers in a meta-analysis of 12 good-quality trials.23
Congestive heart failure | Vitamin E | DM, CVD, or post-infarction | (−) | Low | Vitamin E (300-400 IU/day) was linked with increased CHF hospitalization in 2 trials of high-risk patients.34, 35
Urinary tract infections (UTIs) | Zinc | AMD | (−) | Low | Zinc (80 mg/day) was associated with more UTIs and hospital admissions due to genitourinary causes compared with non-zinc treated subjects in one large study.42
Yellowing of the skin | Beta-carotene Lutein | AMD and general population | (−) | High | Transient yellowing of the skin was frequently reported in trials of beta-carotene24 and in two trials of lutein44
Gastrointestinal (GI) symptoms | Antioxidants | AMD | (−) | High | GI symptoms were the most common adverse effect that led to withdrawal from studies, according to a systematic review of 10 RCTs of antioxidant supplements for AMD.18

GRADE = Grades of Recommendation, Assessment, Development, and Evaluation; ICU = intensive care unit; RCT = randomized controlled trial; AMD = age-related macular degeneration; CHF = congestive heart failure.

* Effect: (+) benefit; (−) harm; (∼) mixed findings/no effect; (0) no evidence.

† GRADE Classification: high = further research is very unlikely to change our confidence on the estimate of effect; moderate = further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate; low = further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate; very low = any estimate of effect is very uncertain.

‡ Trials of antioxidants included treatment with antioxidants alone or combined with carotenoids or other supplements.

While our report notes the uncertainty in the conclusions of many of the included studies, reasonable recommendations can be extended:

- Carotenoid and antioxidants supplements significantly decrease visual loss and can be recommended for patients with Categories 3 and 4 AMD.
- Current literature does not support the use of these supplements for patients with mild AMD.
- Certain nutritional supplements have significant potential harms:
  ○ Increased mortality and congestive heart failure in high risk patients with vitamin E.
  ○ Increased risk of prostate cancer with vitamin E.
  ○ Increased risk of lung cancer among smokers with beta-carotene.