# ASSESSMENT OF METHODOLOGIC QUALITY AND RISK OF BIAS IN RANDOMIZED CONTROLLED TRIALS OF ORAL SUPPLEMENTS FOR AGE-RELATED MACULAR DEGENERATION

Study | Allocation sequence adequately generated | Allocation adequately concealed | Blinding of participants, personnel and outcome assessors | Incomplete outcome data adequately addressed | Absence of selective outcome reporting | Free of other sources of bias | Overall risk of bias | Funding source
AREDS, 2001^10^ | Yes; randomization by treatment center then patients assigned with probability to 1/4 to each group. | Yes | Yes; all meds and placebo were coded and concealed from subjects and examiners…codes were kept only in the coordinating center. | Yes; participants were dropped if not photographed or proper visual acuity measurements were not obtained…these dropped subjects were “evenly distributed across the groups”. Only 2.4% of subjects were lost to follow-up (missed at least 2 consecutive visits). | Yes; each stated outcome measure was reported in addition to adverse events. | Yes | Low | NIH; Bausch & Lomb Inc.
Feher, 2005^16^ | Yes; computer generated randomization sequence. | Yes; staff and subjects were masked. | Yes; all meds and placebos were masked from both subjects and investigators. | Yes; ITT analysis was done; 5/106 failed to complete study and details were reported of each. | Yes; outcomes were reported as indicated. | Yes | Low | Funding NR
Newsome, 1988^11^ | Yes | Yes | Yes | Unclear | Yes | Yes | Low | Research Fund Department of Veterinary Science, Utah State University
Newsome, 2008^14^ | Yes: randomized with 50% likelihood scheme (Yes; 50% likelihood scheme). | Yes; study coordinator provided supplements but did not complete data collection. | Yes; supplements identical in appearance. | Unclear; did not include data from subjects who dropped out or died. | Yes | Yes | Low | Retinal Disease Research Foundation
Richer, 1996^15^ | Yes | Yes | Yes | Unclear: 12 of 71 rate of attrition, but no data provided for those patients, including treatment assignment. | Yes | Yes; 17% loss to follow-up, unclear treatment assignment. | Low | Twin Laboratories, Inc.; Eye Communications, Inc.; Stereo Optical, Inc; Illinois College of Optometry; Pacific University College of Optometry; Ezell Foundation, American Academy of Optometry
Richer, 2004^12^ | Yes; random card. | Yes | Yes | Yes | Yes | Yes | Low | DVA Medical Center, North Chicago; Kemin Foods, Vitacost.com; Nutraceutical Sciences Institute; Great Smokies Diagnostic Laboratory
Stur, 1996^13^ | Unclear; randomization method not described. | Yes | Yes | Yes | Yes | Yes | Low | Austrian Foundation for the Propagation of Scientific Research