# INCLUSION/EXCLUSION CRITERIA

1. Is the full text of the article in English?; Yes......................................................................Proceed to #2; No...................................................................Code X1. STOP; 2. Is the article a controlled clinical trial or a systematic review/meta-analysis of controlled trials comparing the effects of supplemental/non-dietary carotenoids, antioxidants, or omega-3 fatty acids (alone or in combination) with usual care or placebo?; Yes......................................................................Proceed to #3; No...............................................................Code X2. Go to #6; 3. Does the population include adults with age-related macular degeneration?; Yes.......................................................................Proceed to #4; No........................................................................Proceed to #5; 4. Does the study report outcomes that include vision loss, quality of life, functional status, or adverse effects of treatment?; Yes....................................................................Code I4. STOP; No...............................................................Code X4. Go to #6; 5. Does the study report the adverse effects of treatment in a population of ≥100 adults without age-related macular degeneration who were observed for >24 weeks?; Yes.................................................................... Code I5. STOP; No.......................................................Code X5. Proceed to #6; 6. Is the article potentially useful for background, discussion, or reference-mining?; Yes............................................................ Add Code B. STOP; No................................................................................... STOP
PICOTS
Patients: | KQ1: | Adults with age-related macular degeneration
Patients: | KQ2: | Adults, exclude patients with severe chronic illnesses such as end-stage liver disease, ESRD, severe COPD, metastatic cancer, ALS, severe heart failure
Interventions: | | Carotenoids – zeaxanthin, lutein, beta-carotene Antioxidants – zinc, vitamin e, vitamin c Omega-3 fatty acids – alpha linolenic acid (C18:3n-3), docosahexaenoic acid (DHA; C22:6n-3), eicosapentaenoic acid (EPA; C20:5n-3)
Comparators: Placebo, usual care (usual diet)
Outcomes: Vision loss Visual impairment in the best eye defined as: ≤ 20/60 by Snellen acuity; or ≤ 6/18 metric acuity; or doubling of the visual angle (e.g. 20/50 to 20/100); or ≥ three lines of loss; or ≥ 15 letters lost; or progression to advanced disease (either geographic atrophy or wet macular degeneration); quality of life; functional status.