# SEARCH STRATEGY

Ovid MEDLINE® and Ovid OLDMEDLINE® 1947 to February Week 1 2011 -- Date Searched 2011/02/15 - QUESTION 1
| Concept | Search String | N
1 | Age-related macular degeneration | Exp macular degeneration/ OR geographic atrophy/ OR macular edema/ OR wet macular degeneration/ OR macular degeneration.mp OR AMD.mp OR ((moderate OR intermediate) ADJ5 (macular degeneration OR AMD OR maculopath$ OR macular dystroph$)).mp OR (age ADJ4 maculopath$).mp OR (age ADJ4 macular).mp OR (retinal ADJ4 degeneration).mp OR macular dystrophy.mp OR Retinal drusen/ OR retinal druse$.mp OR Retinal neovascularization/ OR Retinal Pigment Epithelium/ OR retinal pigment epithelium hyperplasia.mp OR RPE.mp OR retinal pigment epithelium atroph$.mp OR retinal pigment epithelium depigmentation.mp OR geographic atrophy.mp OR Choroidal neovascularization/ OR Choroidal neovascularization.mp OR AREDS stage 1.mp OR AREDS stage 3.mp OR subjacent retinal pigmentation epithelium.mp OR choriocapillaris.mp OR lipofuscin.mp OR neovascular AMD.mp OR CNV.mp OR macular pigment optical density.mp OR MPOD.mp OR (age ADJ1 related ADJ1 eye ADJ1 disease ADJ1 study).mp OR Pigment epithelium of eye/ OR Macula Lutea/ OR fovea centralis/ OR Retinal detachment/ | 57,272
2 | Nutritional supplements, carotenoids, antioxidants, omega 3 fatty acids | Dietary supplements/ OR (dietary ADJ1 supplement$).mp OR (nutritional ADJ1 supplement$).mp OR Vitamins/ OR Carotenoids/ OR carotenoid$.mp OR zeaxanthin.mp OR Lutein/ OR lutein.mp OR Beta carotene/ OR beta-carotene.mp OR beta carotene.mp OR Antioxidants/ OR antioxidant$.mp OR Zinc/ OR zinc.mp OR Vitamin E/ OR (vitamin ADJ1 E).mp OR Ascorbic acid/ OR (vitamin ADJ1 C).mp OR Fatty Acids, Omega-3/ OR omega 3 fatty acids.mp OR alpha-Linolenic Acid/ OR alpha linolenic acid.mp OR Docosahexaenoic Acids/ OR Docosahexaenoic acid.mp OR Eicosapentaenoic Acid/ OR Eicosapentaenoic acid.mp OR tocopherols.mp | 268,101
3 | Cochrane Reviews Clinical Hedge | (randomized controlled trial OR controlled clinical trial OR meta-analysis).pt OR randomized.ab OR placebo.ab OR drug therapy.fs OR randomly.ab OR trial.ab OR groups.ab OR (systematic ADJ1 review).mp | 2,611,405
4 | Q1: | 1 AND 2 AND 3 | 523

EMBASE -- Date Searched 2011/03/17 - QUESTION 1
| Concept | Search String | N
1 | Age-related macular degeneration | ‘retina macula age related degeneration’/exp OR ‘retina macula degeneration’/exp OR ‘retina macula edema’/exp OR ‘drusen’/ exp OR ‘retina neovascularization’/exp OR ‘pigment epithelium’/exp OR ‘subretinal neovascularization’/exp OR ‘retina macula lutea’/exp OR ‘retina fovea’/exp OR ‘retina detachment’/exp OR ‘macular degeneration’/de OR ‘macular degeneration’ OR ‘geographic atrophy’ OR ‘macular edema’/de OR ‘macular edema’ OR ‘wet macular degeneration’ OR ‘amd’/de OR amd OR (moderate OR intermediate) NEAR/5 (‘macular degeneration’ OR amd OR maculopat* OR ‘macular dystrophy’) OR age NEAR/4 maculopath* OR age NEAR/4 macular OR retinal NEAR/4 degenerat* OR ‘macular dystrophy’/de OR ‘macular dystrophy’ OR rpe OR ‘retinal pigment epithelium atrophy’ OR ‘retinal pigment epithelium depigmentation’ OR ‘areds stage 1’ OR ‘areds stage 3’ OR ‘subjacent retinal pigmentation epithelium’ OR ‘choriocapillaris’/de OR choriocapillaris OR ‘lipofuscin’/ de OR lipofuscin OR ‘neovascular amd’ OR cnv OR ‘macular pigment optical density’ OR mpod AND [embase]/lim *search also required that the term be a major focus of the article | 46,770
2 | Nutritional supplements, carotenoids, antioxidants, omega 3 fatty acids | ‘diet supplementation’/exp OR ‘vitamin’/exp OR ‘carotenoid’/exp OR ‘xanthophyll’/exp OR ‘beta carotene’/exp OR ‘antioxidant’/exp OR ‘zinc’/exp OR ‘alpha tocopherol’/exp OR ‘ascorbic acid’/exp OR ‘omega 3 fatty acid’/exp OR ‘linolenic acid’/exp OR ‘docosahexaenoic acid’/exp OR ‘icosapentaenoic acid’/exp OR ‘tocopherol’/exp OR ‘zeaxanthin’/exp | 538,080
3 | Cochrane Reviews Clinical Hedge | ‘randomized controlled trial’/exp OR ‘controlled clinical trial’/exp OR ‘meta analysis’/exp OR ‘systematic review’/exp *Also searched as keyword and major focus of article | 380,031
4 | Q1: | 1 AND 2 AND 3 | 146

COCHRANE (Cochrane Database of Systematic Reviews; Database of Abstracts of Reviews of Effects; Cochrane Central Register of Controlled Trials) -- Date Searched 2011/03/28 - QUESTION 1
| Concept | Search String | N
1 | Age-related macular degeneration | “macular degeneration” OR “geographic atroph*” OR “macular edema” OR AMD “macular dystroph*” OR “Retinal druse*” OR “Retinal neovascularization” OR “Retinal Pigment Epithelium” OR RPE OR “Choroidal neovascularization” OR AREDS OR choriocapillaris OR lipofuscin OR “neovascular AMD” OR CNV OR “macular pigment optical density” OR MPOD OR “Macula Lutea” OR “fovea centralis” OR “Retinal detachment” (Title, Abstracts, or Keywords search) | 28
2 | Nutritional supplements, carotenoids, antioxidants, omega 3 fatty acids | Supplement* OR vitamin* OR carotenoid* OR xanthophyll OR beta carotene* OR antioxidant* OR zinc OR tocopherol* OR “ascorbic acid” OR “omega 3 fatty acid*” OR linolenic OR docosahexaenoic OR icosapentaenoic OR zeaxanthin (Title, Abstracts, or Keywords search) | 530
4 | Q1: | 1 AND 2 | 3

SCOPUS -- Date Searched 2011/03/28 - QUESTION 1
| Concept | Search String | N
1 | Age-related macular degeneration | macular degeneration OR geographic atroph* OR macular edema OR AMD macular dystroph* OR Retinal druse* OR Retinal neovascularization OR Retinal Pigment Epithelium OR RPE OR choroidal neovascularization OR AREDS OR choriocapillaris OR lipofuscin OR neovascular AMD OR CNV OR macular pigment optical density OR MPOD OR Macula Lutea OR fovea centralis OR Retinal detachment (Title, Abstracts, or Keywords search) | 73,074
2 | Nutritional supplements, carotenoids, antioxidants, omega 3 fatty acids | Supplement* OR vitamin* OR carotenoid* OR xanthophyll OR beta carotene* OR antioxidant* OR zinc OR tocopherol* OR “ascorbic acid” OR “omega 3 fatty acid*” OR linolenic OR docosahexaenoic OR icosapentaenoic OR zeaxanthin | 4,296
4 | Q1: | 1 AND 2 | 73

Conference Papers Index -- Date Searched 2011/03/28 - QUESTION 1
| Concept | Search String | N
1 | Age-related macular degeneration | macular degeneration OR geographic atroph* OR macular edema OR AMD macular dystroph* OR Retinal druse* OR Retinal neovascularization OR Retinal Pigment Epithelium OR RPE OR choroidal neovascularization OR AREDS OR choriocapillaris OR lipofuscin OR neovascular AMD OR CNV OR macular pigment optical density OR MPOD OR Macula Lutea OR fovea centralis OR Retinal detachment (Keywords search) | 3,832
2 | Nutritional supplements, carotenoids, antioxidants, omega 3 fatty acids | Supplement* OR vitamin* OR carotenoid* OR xanthophyll OR beta carotene* OR antioxidant* OR zinc OR tocopherol* OR “ascorbic acid” OR “omega 3 fatty acid*” OR linolenic OR docosahexaenoic OR icosapentaenoic OR zeaxanthin (Keywords search) | 22,207
4 | Q1: | 1 AND 2 | 68

Ovid MEDLINE® and Ovid OLDMEDLINE® 1947 to February Week 4 2011 -- Date Searched 2011/02/15 - QUESTION 2 SEARCH
| Concept | Search String | N
1 | Population | Aging/ OR aging.mp. OR ageing.mp. OR Aged/ OR aged.mp. OR “Aged, 80 and over”/ OR frail elderly/ OR Middle aged/ OR middle aged.mp. OR elder$.mp. OR senior$.mp. OR geriatric$.mp OR age-related.mp. OR (age adj1 related).mp. | 3,562,146
2 | Zeaxanthin, lutein, beta-carotene, zinc, vitamin e, vitamin c, alpha linolenic acid, DHA, EPA | zeaxanthin.mp OR Lutein/ OR lutein.mp OR Beta carotene/ OR beta-carotene.mp OR beta carotene.mp OR Zinc/ OR zinc. mp OR Vitamin E/ OR (vitamin ADJ1 E).mp OR tocopherols.mp OR Ascorbic acid/ OR (vitamin ADJ1 C).mp OR alpha-Linolenic Acid/ OR alpha linolenic acid.mp OR Docosahexaenoic Acids/ OR Docosahexaenoic acid.mp OR Eicosapentaenoic Acid/ OR Eicosapentaenoic acid.mp | 160,101
3 | Cochrane Reviews Clinical Hedge | (randomized controlled trial OR controlled clinical trial OR meta-analysis).pt OR randomized.ab OR placebo.ab OR drug therapy.fs OR randomly.ab OR trial.ab OR groups.ab OR (systematic ADJ1 review).mp | 2,656,105
4 | Harms | unsafe.mp OR safety.mp OR harm.mp OR harms.mp OR complication$.mp OR poison$.mp OR risk$.mp OR AE.fs OR MO.fs OR PO.fs OR TO.fs OR CT.fs OR side-effect$.mp OR (undesirable ADJ1 effect$).mp OR (treatment ADJ1 emergent).mp OR tolerab$.mp OR toxic$.mp OR adrs.mp OR (adverse ADJ2 (effect or effects or reaction or reactions or event or events or outcome or outcomes)).mp | 3,492,667
5 | Q2: Population, dietary supplements, study methods, and harms | 1 AND 2 AND 3 AND 4 | 3,514

Embase -- Date Searched 2011/03/17 - QUESTION 2
| Concept | Search String | N
1 | Population | ‘aged’/mj OR ‘frail elderly’/mj OR ‘elderly’/mj OR ‘very elderly’/mj OR ‘aged hospital patient’/mj OR ‘middle aged’/mj OR senior* OR geriatric* OR ‘age near/1 related’ AND [embase]/lim | 154,441
2 | Zeaxanthin, lutein, beta-carotene, zinc, vitamin e, vitamin c, alpha linolenic acid, DHA, EPA | ‘diet supplementation’/mj OR ‘carotenoid’/mj OR ‘xanthophyll’/mj OR ‘beta carotene’/mj OR ‘antioxidant’/mj OR ‘zinc’/ mj OR ‘alpha tocopherol’/mj OR ‘ascorbic acid’/mj OR ‘omega 3 fatty acid’/mj OR ‘linolenic acid’/mj OR ‘docosahexaenoic acid’/mj OR ‘icosapentaenoic acid’/mj OR ‘tocopherol’/mj OR ‘zeaxanthin’/mj AND [embase]/lim | 98,250
3 | Cochrane Reviews Clinical Hedge | ‘randomized controlled trial’/mj OR ‘randomized controlled trial’/de OR ‘randomized controlled trial’ OR ‘controlled clinical trial’/mj OR ‘controlled clinical trial’/de OR ‘controlled clinical trial’ OR ‘meta analysis’/mj OR ‘meta analysis’/de OR ‘meta analysis’ OR ‘systematic review’/mj OR ‘systematic review’/de OR ‘systematic review’ AND [embase]/lim *also searched as keyword and main topic of article | 380,031
4 | Harms | ‘adverse drug reaction’/mj OR ‘adverse drug reaction’ OR ‘drug induced disease’/mj OR ‘drug induced disease’ OR ‘complication’/mj OR ‘complication’ OR ‘intoxication’/mj OR ‘intoxication’ OR ‘toxicity’/mj OR ‘toxicity’ OR ‘drug hypersensitivity’/mj OR ‘drug hypersensitivity’ OR unsafe OR ‘safety’/mj OR safety OR harm OR harms OR complication* OR poison* OR risk* OR undesirable NEAR/1 effect OR treatment NEAR/1 emergent OR tolerab* OR toxic* OR adrs OR adverse NEAR/2 (effect OR effects OR reaction OR reactions OR event OR events OR outcome OR outcomes) AND [embase]/lim | 3,965,190
5 | Q2: Population, dietary supplements, study methods, and harms | 1 AND 2 AND 3 AND 4 | 108

SCOPUS -- Date Searched 2011/03/17 - QUESTION 2
| Concept | Search String | N
1 | Population | aged OR elderly OR “middle aged” OR senior* OR geriatric* OR “age related” in TITLE-ABS-KEY | 3,178,852
2 | Zeaxanthin, lutein, beta-carotene, zinc, vitamin e, vitamin c, alpha linolenic acid, DHA, EPA | zeaxanthin OR lutein OR “Beta carotene” OR zinc OR “Vitamin E” OR tocopherol* OR “Ascorbic acid” OR “vitamin C” OR alpha-linolenic OR docosahexaenoic OR eicosapentaenoic in TITLE-ABS-KEY-AUTH | 447,672
3 | Cochrane Reviews Clinical Hedge | “randomized controlled trial*” OR “controlled clinical trial*” OR “meta analysis” OR “systematic review*” TITLE-ABS-KEY-AUTH | 529,484
4 | Harms | “adverse drug reaction*” OR “adverse reaction*” OR complication* OR toxic* OR poison* OR harm* OR unsafe OR tolerab* OR adverse outcome* OR adverse event* OR adverse effect* TITLE-ABS-KEY-AUTH | 252,917
5 | Q2: Population, dietary supplements, study methods, and harms | 1 AND 2 AND 3 AND 4 | 309

Cochrane Library (Cochrane Database of Systematic Reviews; Database of Abstracts of Reviews of Effects; Cochrane Central Register of Controlled Trials) --Date Searched 2011/03/25 - QUESTION 2
| Concept | Search String | N
1 | Population | aged OR elderly OR “middle aged” OR senior* OR geriatric* OR “age related” (Title, Abstracts or Keywords search) | 1,238
2 | Zeaxanthin, lutein, beta-carotene, zinc, vitamin e, vitamin c, alpha linolenic acid, DHA, EPA | zeaxanthin OR lutein OR “Beta carotene” OR zinc OR “Vitamin E” OR tocopherol* OR “Ascorbic acid” OR “vitamin C” OR alpha-linolenic OR docosahexaenoic OR eicosapentaenoic (Title, Abstracts or Keywords search) | 79
3 | Harms | reaction* OR complication* OR toxic* OR poison* OR harm* OR unsafe OR safety OR tolerab* OR adverse (Title, Abstracts or Keywords search) | 4,283
4 | Q2: Population, dietary supplements, study methods, and harms | 1 AND 2 AND 3 | 23

Conference Papers Index -- Date Searched 2011/03/25 - QUESTION 2
| Concept | Search String | N
1 | Population | aged OR elderly OR “middle aged” OR senior* OR geriatric* OR “age related” (Keyword search) | 21,302
2 | Zeaxanthin, lutein, beta-carotene, zinc, vitamin e, vitamin c, alpha linolenic acid, DHA, EPA | zeaxanthin OR lutein OR “Beta carotene” OR zinc OR “Vitamin E” OR tocopherol* OR “Ascorbic acid” OR “vitamin C” OR “omega 3 fatty acid*” OR alpha-linolenic OR docosahexaenoic OR eicosapentaenoic (Keyword search) | 9,376
3 | Harms | reaction* OR complication* OR toxic* OR poison* OR harm* OR unsafe OR safety OR tolerab* OR adverse (Keyword search) | 98,395
4 | Q2: Population, dietary supplements, study methods, and harms | 1 AND 2 AND 3 | 1