# SUMMARY AND DISCUSSION

Our systematic review focused on modifiable risk factors, such as health behaviors of patients with MS. We systematically searched for, documented, and synthesized studies available in the international literature on modifiable risk factors and the effect of modification therapies.

The review addressed a broad and very complex research field and a large number of studies contributed to this review. Literature searches were comprehensive and exploratory in nature and were not limited to a narrow set of known risk factors. Few prospective studies were identified to inform the association between modifiable risk factors and MS progression, limiting the conclusions that can be drawn from the existing literature for KQ1. Furthermore, while the review made every effort to locate studies relevant to KQ2 (exposure during military service), only a very small number of studies was identified. Although a number of interventions have been tested in RCTs, many were not designed to assess the effect on MS progression, also limiting the conclusions that can be drawn from the intervention literature addressed in KQ3.

We did not find variables that were identified as valid risk factors of MS progression and that have been shown in intervention studies to improve MS progression. However, the review systematically explores and catalogues what is currently known in this research field, highlights promising areas, and identifies future research needs to address the progression of MS.

## SUMMARY OF EVIDENCE FOR KQ1 What modifiable epidemiologic factors are related to multiple sclerosis progression following diagnosis?

Our literature review identified a large number of modifiable epidemiologic factors that have been assessed in the context of MS progression. However, study designs, operationalizations of risk factors, and outcome assessment measures varied widely.

A substantial amount of research has been dedicated to the role of vitamin D in MS progression. Our synthesis shows a weak but consistent negative correlation between 25(OH)D levels and EDSS scores across studies. Evidence comes primarily from concurrent studies which assess the physiological level and the disability status at the same time. Hence, this result should be interpreted as an association without causal interpretation. Low vitamin D levels may be the cause, the effect, or a covariate of EDSS levels. In addition, whether the physiological levels can be directly influenced by patients is an unresolved question. The association has also been shown in 2 prospective studies that reported on this outcome and although there was some evidence of publication bias, an adjusted analysis found a very similar effect. We did not find studies reporting on other operationalizations of the role of vitamin D, such as sun exposure or use of supplements, that could be combined, and we did not find studies reporting on the effect of vitamin D on the change from relapsing-remitting to secondary progressive MS. The international literature has linked MS to vitamin D deficiency and suggests additional functions outlining why high levels of vitamin D may be beneficial for MS patients (eg, anti-inflammatory aspects of vitamin D).^4,129^

Smoking has also been addressed in a large number of studies and was associated with an increased risk of progression in MS patients. The association was shown in studies predicting time to EDSS scores of 6 (use of cane, crutch, or brace) as well as conversion to secondary progression. Our confidence in the exact size of effect is somewhat limited due to unexplained heterogeneity (moderate quality of evidence). Our pooled estimate was statistically significant but lower than that reported by a 2011 meta-analysis. The earlier existing meta-analysis was based on fewer studies and did not find a statistically significant effect, and concluded at the time that smoking is important in determining MS susceptibility but the effect on the progression of disease is less certain.^130^ The now available literature suggests that smoking is an important modifiable risk factor for MS progression. This is of particular importance as it is a risk factor that can be directly influenced by MS patients.

There is low quality of evidence that epidural analgesics during childbirth are associated with EDSS scores. This outcome has been addressed in retrospective as well as prospective studies but all existing studies report on disability levels across study samples, not direct measures of progression in individuals such as time to secondary progression.

The risk factors sun exposure, month of birth, diet, fish consumption, alcohol-related predictors, exercise, oral contraception, and education have been addressed in more than one study and were documented in detail in the summary of findings section. It was not possible to derive specific evidence statements due to the unique operationalization of risk factors and outcome measures; however, in particular the role of sun exposure and alcohol-related variables should be investigated further.

The evidence tables document a large range of potential risk factors such as: cesarean delivery; breast feeding; having been breast fed; obstetrical and spinal anesthesia; childhood maltreatment; working outdoors; individual health promoting lifestyle domains; meditation practice; insurance coverage; medical care satisfaction variables; exposure to different types of animals; coal heating; wood heating; humid living space; no sewage system; no piped water; type of environment (eg, farm); specific diet factors such as coffee consumption, liver consumption, vitamin supplementation, fortified foods, vegetarian diet; cod liver oil intake; occupational status; deployment to a war theater; being a Veteran; and earthquake experience. These were addressed in single studies and have not been replicated in other studies.

The review explored a large number of potential risk factors but shows that in many cases, the existing evidence base investigating an association is insufficient to make evidence statements for specific outcomes and results. This is illustrated by the following examples. Our systematic review showed that the evidence for an association between progression of MS and dietary factors is sparse. We did not identify more than one study reporting on the same diet and reporting on the same outcome measure. Similarly, a Cochrane review on dietary interventions in MS highlighted that a number of diets for MS (eg, Swank Diet) have been proposed; however, dietary habits in MS patients have not been extensively studied or reported.^12^ Furthermore, physical exercise has been addressed in a number of published studies, both as a correlate of disability and its predictive validity for MS progression. Study results varied by analytic design. Lower physical exercise can be the cause, the effect, or a covariate of higher EDSS scores. We did not identify more than one study reporting on the same risk factor operationalization and MS progression outcome measure. Hence, the existing evidence base is still very limited. Approaches to offer physical exercise to MS patients are traditionally based on optimizing daily functioning, but whether exercise has a role in slowing progression of MS has also been raised as a research question.^131-133^

## SUMMARY OF EVIDENCE KQ2 What environmental exposures prior to or during military service are related to multiple sclerosis progression following onset symptoms?

Only very few studies were identified that reported on exposures prior to and during military services associated with MS progression (KQ2) in active military personnel or Veterans. Evaluated risk factors in existing studies include only a small number of potentially relevant exposures such as deployment.

The quality of the evidence across studies was determined to be insufficient for evidence statements. None of the studies employed a prospective study design and risk factors were addressed in single studies without replication in other studies. All potential risk factors were reported in only one included study without replication in another participant sample. Hence, the available evidence is not suitable to answer the review question.

## SUMMARY OF EVIDENCE KQ3 Among identified risk factors for progression, what treatment / risk factor modification therapies have been shown to delay or hasten the progression of MS once it has initiated?

Our literature searches identified a substantial number of studies that have addressed modifiable risk factors; however, all addressed exercise programs, dietary interventions, or vitamin D supplementation.

Exercise interventions did not demonstrate a statistically significant effect on EDSS scores comparing intervention and untreated control groups across all studies reporting on this outcome. However, sensitivity analyses indicated that, adjusting for baseline imbalances, small effects on EDSS become apparent (0.20 point difference between treatment groups). Studies were not designed to assess EDSS changes or other measures of progression, study sample sizes were very small with indications of baseline imbalances, and the interventions may have been too short to achieve and to detect changes with standard diagnostic criteria. The negative results should not be interpreted as exercise not being beneficial in MS in general. Exercise in MS patients may have many positive effects^132^ and a recent systematic review^134^ addressing a range of outcomes concluded that exercise may be recommended for rehabilitation. Our review aimed to detect an effect for a very specific outcome – progression of MS.

The identified data did not indicate a statistically significant positive effect of dietary interventions that affected the progression of MS. This result mirrors the conclusion of an existing Cochrane review on dietary interventions for MS that included studies published to November 2011.^12^ The review reported that polyunsaturated fatty acids seem to have no major effect on disease progression but cautioned also that evidence statements are limited due to uncertain quality of the studies.

Individual studies and the pooled result showed a trend for an effect favoring vitamin D supplementation in MS patients but the statistical significance depended on the effect measure. Our confidence in the evidence for the absence of an effect is limited given that the existing studies were small and they may lack statistical power to detect small treatment effects. A Cochrane review that searched for intervention studies in May 2010 identified only one study; all additional studies shown in our meta-analysis were published after this date. The review concluded that the level of evidence for the effectiveness of vitamin D supplementation does not allow confident decision-making about the use of vitamin D in MS.^4^ Any potential treatment effects are likely to be small, with an estimated difference of 0.22 points in EDSS scores between intervention and control groups.

Finally, smoking, a risk factor for progression with a stronger evidence base, has not been addressed in RCTs to assess the effects of smoking cessation interventions on progression in MS patients. This is unfortunate because some risk factor studies suggested that negative consequences of smoking can be reversed in ex-smokers, suggesting that this risk factor could be amenable to intervention.^46^

## LIMITATIONS

It should be noted that this review was restricted to patient-reported measures of MS progression and disability. Other progression measures such as MRI results are also of interest to clinicians and can make additional contributions to this complex research field.

Furthermore, due to resource constraints, this review was limited to English-language publications. Although we included several international studies, the language restriction will have missed some studies, in particular older studies contributing to research on MS progression.

This review identified a large number of studies contributing to the evidence base on modifiable risk factors associated with MS progression. However, the evidence base is limited due to the small number of prognostic studies and the small number of studies reporting on direct measures of progression (eg, conversion to secondary progressive MS) rather than proxies such as MS disability status.

We converted statistics to the extent possible for this review. Nonetheless we were often not able to summarize results across studies due to lack of reporting of key variables, such as point estimates and measures of dispersion, in addition to the statistical significance of the presence or absence of associations. Due to the timeframe and lack of resources the review is entirely based on published literature and did not contact authors for missing information or additional data; furthermore, several included studies have been published decades ago, making it unlikely that additional data is still available.

### Applicability of Findings to the VA Population

We found no indication that risk factor results and treatment effects are not applicable to the VA population. However, the existing evidence does not permit analyses to test this hypothesis by identifying moderator effects linking study populations to differential effects. There are very few risk factor or intervention studies reporting specifically on VA samples.

## RESEARCH GAPS/FUTURE RESEARCH

Our systematic review showed that more prospective research studies are needed to allow predictions and meaningful interpretation of risk factor analyses. Furthermore, it is imperative that risk factor studies report more details (eg, mean EDSS scores and a measure of dispersion), more measures of progression, and/or more analyses (eg, reporting on EDSS scores means as well as time to progression to specific EDSS benchmarks). While many individual studies do not have sufficient statistical power to detect small effects of risk factors on progression, studies may contribute to future meta-analyses. We identified a number of areas with published research on a risk factor of interest, but due to the unique operationalization of predictor and outcome measure, it was not possible to adequately synthesize results across studies.

Although our review addressed a broad research field, there are other potential risk factors that were outside the scope of this review, such as comorbidities.^11^ There is a growing literature on MS comorbidities, including obesity and the associations of body weight and MS progression, which warrants an individual systematic review.^135,136^ Future reviews should in particular address the role of treatable comorbidities in MS progression. Scoping searches also identified a large literature base evaluating the effect of pregnancies. However, any association needs to be interpreted with caution. While the data may suggest a protective effect, reverse causality cannot be ruled out – a MS diagnosis and perceived progression may affect reproductive decision making.^137^

Furthermore, this review did not target psychological variables, such as depression, anxiety, coping strategies, social functioning, distress, anger, and other emotions and cognitive styles, which may be reactions to MS progression and/or contributing factors to MS progression. Although variables have been assessed in the literature, very often, these have been studied as correlates of the disease, and while many studies have tried to predict psychological variables with MS progression, some have used the psychological variables as predictors for MS progression. These variables should be assessed in prospective risk factor studies to establish the temporal chain of events in order to establish a prognostic link between these variables and MS progression. However, even if a link can be established, it is a different matter to show that the psychological variables can a) be modified and b) the modification has an effect on progression; hence, intervention studies testing the modification therapy will be subsequently needed.

Generally, more prospective risk factor studies are needed that allow determining a temporal sequence of events and that address the direction of associations. For example, a number of studies have reported on alcohol-related measures and showed better outcomes associated with specific operationalizations of alcohol use or misuse, but the available studies used primarily concurrent data (correlating current alcohol intake and current disability) and an alternative interpretation of this “protective” effect of alcohol is that more disabled people drink less alcohol because of their disability. Sun exposure should also be evaluated further in order to replicate identified associations of specific operationalizations of the predictor variable and MS disability and progression measures. Prospective studies are needed to provide more information on the role of sun exposure and alcohol consumption (and the optimum amount) in MS progression.^11^

Finally, intervention studies testing the effect of interventions on MS progression should determine the statistical power needed to detect a difference between treatment groups. This is in particular needed for vitamin D supplementation trials. In addition, more research on exercise interventions is warranted with studies that are adequately powered and interventions of sufficient duration to potentially influence MS progression. Effects of smoking cessation interventions should be determined in intervention studies given the association between smoking and MS progression. Furthermore, while a substantial number of intervention studies exist that have reported on disease status and disability measures, larger studies reporting on direct progression measures are urgently needed.

## CONCLUSIONS

A large number of studies is available to contribute to the growing research literature on modifiable risk factors and MS progression but the research field is very complex.

Risk factor studies used diverse operationalizations of risk factors and different outcome measures, and more prospective studies are needed. Most consistent results were shown for the association between EDSS scores and vitamin D levels. Smoking was associated with a faster progression of MS in smokers compared to nonsmokers.

Risk factors in Veterans and active military personnel were one of the key questions for this review but very few studies are available to inform on this participant subgroup.

We did not identify interventions that showed a statistically significant effect of exercise, diet, or vitamin D supplementation on EDSS scores across studies. However, studies were not designed to assess effects on MS progression. More research is needed, in particular, on interventions for smoking cessation, adequately powered vitamin D supplementation RCTs, and RCTs testing the effects of long-term exercise interventions.