# RESULTS

## LITERATURE FLOW

The literature search identified a large number of citations (N = 8,594). We selected 455 potentially relevant publications to be obtained as full text in order to screen them against the predetermined inclusion criteria.

We obtained a large number of publications as full text and checked studies for the outcome of interest after piloting the inclusion criteria in the first set of citations. Publications did not systematically mention progression in the title or abstract of the publication; hence, a large number of studies was obtained as full text and results sections were carefully screened for data relevant to MS progression.

In total, 300 publications were excluded because they did not meet one or more of the inclusion criteria. The list of excluded studies and the reasons for exclusion are documented in Appendix B. A large proportion of the studies was excluded because the full-text review showed that the study did not report on MS progression. The second-largest reason for exclusion was associated with studies not reporting on modifiable risk factors (Exclude-Intervention/Exposure).

In total, 95 studies^19-112^ met inclusion criteria and contributed to answering the review questions. Of these, 59 studies contributed to KQ1. Despite the extensive search in general and specialist databases for military research, we only identified 4 studies that provided data for KQ2. In total, 36 RCTs were identified that contributed to KQ3.

Figure 1 Literature Flow Chart

Note: Some included studies contributed to more than one KQ.

## KEY QUESTION 1 What modifiable epidemiologic factors are related to multiple sclerosis progression following diagnosis?

Risk factor studies meeting inclusion criteria were published between 1973 and 2015, with a large proportion of studies having been published in the last 3 years. Of note, no study was excluded due to the publication year for this review and all databases were searched without date restriction.

Studies were conducted in the US, Canada, Australia, Japan, Iran, Italy, Belgium, UK, the Netherlands, France, Sweden, Germany, Turkey, and Finland, and some were international samples based on online surveys. Studies identified participants through hospital records or surveyed members of MS registries. Most studies used unselected samples that included a range of MS forms.

Studies assessed a large variety of modifiable epidemiological factors and used different operationalizations of potential risk factors (eg, average number of cigarettes smoked per day, exercise / physical activities assessed with the revised Health Promoting Lifestyle Profile [HPLP-II]). Some studies assessed the current status while others assessed lifetime prevalence (eg, ever smokers).

Included studies used a broad range of outcome measures such as EDSS scores, other patient-reported scale scores, correlations with EDSS scores or other measures of disease status, time to EDSS 6, time to EDSS 4, time to secondary progression, or time to wheelchair dependency. Some studies used standardized scales such as the EDSS while others reported on clinician-defined outcomes (eg, clinical deterioration).

The research study pool included 13 prospective studies.^20,30,35,69,72,76,87,91,96-98,112,113^ These studies assessed participants at 2 or more different points in time and are better suited to make predictions (rather than establish concurrent associations, or relying on retrospective assessments from memory about factors experienced in the past).

Details of all included studies are presented in the evidence tables. We grouped studies exclusively reporting on vitamin D or sun exposure, studies reporting on childbirth-related factors, studies investigating the role of smoking, studies reporting on diet and nutrition, and studies reporting on unique factors such as childhood trauma. The last evidence table summarizes studies that investigated more than one risk factor of interest for this review.

Of the single-factor studies, the largest group addressed vitamin D. Vitamin D can be absorbed from exposure from sunlight, from diet, or from dietary supplements. The first evidence table for KQ1 documents how published studies have operationalized this potential risk factor for MS progression.

Table 1 Evidence for KQ1 (MS Progression Risk Factors): Vitamin D or Sunshine Exposure

ID Assessment timing | Region | Sample MS form | Predicted outcome | N | Design Analysis | Risk factors | Covariates | EDSS results | Other results
Ascherio, 2014^20^ prospective | 18 European countries, Israel, and Canada | Sample from BENEFIT trial, presenting with first episode of neurological dysfunction suggestive of MS Form N/A; Poser criteria, McDonald 2001 criteria | EDSS changes | 465 | Time series Multivariate analysis | 25(OH)D level | Sex, age at baseline, treatment group, baseline T2 lesion score, type of clinically isolated syndrome (BMI and steroid use explored) | A 50-nmol/L increase in 25(OR)D levels was associated with a reduction of 0.16 steps in EDSS scores (p = 0.11); 25(OH)D concentrations >/= 50nmol/L predicted lower EDSS during subsequent 4 years (p = 0.004)
Dastagir, 2013^33^ concurrent | US | MS center patients Relapsing MS patients (R-R or SP); criteria N/A | EDSS score | 100 | Cross-sectional Multiple regression | Vitamin D levels | Race, age, disease duration, time of onsite of Rx | Vitamin D level showed significant inverse correlation with EDSS (data N/A)
Fragoso, 2012^39^ retrospective | South America | Patients with MS from Argentina, Brazil, Chile, and Peru, mean age 40.8 (SD 12.6) years, mean disease duration 8.2 (SD 15.5) years, 29.1% female Form N/A, mean EDSS 2.48 (SD 2.34); Poser criteria, McDonald 2005 criteria, McDonald 2001 criteria | Progression to EDSS 6 | 1207 cases, 1207 controls | Case-control ANOVA, chi-square test, linear regression, correlation | Month of birth in different latitudes of South America | Latitude, age, disease duration, gender | No difference in disease progression in relation to the month or season of birth (numerical data N/A)
Gelfand, 2011^41^ concurrent | US | African Americans with MS, mean age 21.9 (SD 11.2) years, 55.9% female, 18.7% European genetic ancestry Form N/A, MSSS 6.1(CI 4.8, 8.1); McDonald 2001 criteria | MSSS score | 339 cases, 342 controls | Cross-sectional Correlation | 25(OH)D levels | Age, gender, HLA-DRB1^*^15 status, latitude | | No linear association between MSSS and vitamin D status (p = 0.57), no association between low vs high MSSS and deseasonalized or unadjusted vitamin D (OR 0.79, p = 0.86; OR 1.01, p = 0.97)
Hatamian, 2013^45^ concurrent | Iran | Patients of MS Society with R-R confirmed by clinical findings and MRI, mean age 28.4 yrs, 70% female R-R with EDSS score < 5.5 and in remission; criteria N/A | EDSS score | 52 MS patients, 52 healthy participants | Case-control Multiple linear regression analysis | 25(OH)D level | Duration of disease, sex, age | Vitamin D was not associated with EDSS (beta = -0.01, p = 0.34) in univariate analysis; in adjusted model duration of disease was the only significant contributor to EDSS
Lucenti, 2014^58^ retrospective | Italy | MS patients, mean age 32 (SD 10.4) years, mean disease duration of 8.8 (SD 7.8) years, 65% female, 84% R-R and SP, 16% PP, median MSSS 3.86 (CI 3.55, 4.14); criteria N/A | MSSS score | 1782 | Cross-sectional Quantile regression | Month of birth | Gender, age at onset, clinical form | | Month of birth had no impact on disease progression
Knippenberg, 2011^50^ concurrent | The Netherlands | Outpatients with MS, 73% female, mean age 44.2 R-R, SP, PP; criteria N/A | EDSS score | 59 | Cross-sectional Correlation | 25(OH)D serum level | N/A | Vitamin D did not reach statistical significance (r = -0.198)
Koch, 2008^51^ retrospective | Canada,The Netherlands | Canadian MS database 29.6% males, mean age at onset 30.6, mean disease duration 20.1 years (SD 9.9); Dutch database 33.3% males, mean age at onset 32.9, mean disease duration 17.98 years ( SD 10.4) Canadian: 12.4% PP, 87.2% R-R; Dutch 29.4% PP, 87.6% R-R; Poser criteria | Time to EDSS 6, time from MS onset to secondary progression, age at secondary progression | N = 2837; N = 810 | Cross-sectional Kaplan-Meier survival analysis | Month of birth | N/A | No association between the month or season of birth and disease progression could be found that was reproducible in both cohorts
Kragt, 2009^53^ concurrent | Europe, The Netherlands | MS patients 68% female, 98% Caucasian, and mean 11.2 years duration, 98% born in the Netherlands, 64% of women premenopausal Definitive MS; Poser criteria | EDSS score | 103 MS and 110 healthy controls | Case-control Correlation | Summer and winter serum 25(OH)D concentrations | N/A | No significant correlation between summer and winter vitamin D and summer and winter EDSS in sample; but in women r = -0.25 (summer, p = 0.044) and r = -0.29 (winter, p = 0.020)
Niino, 2013^70^ concurrent | Japan | MS patients from Medical Center and Neurology Clinic, 90% female, mean age 40.8, mean age onset 30.1 years, mean and median age of disease duration 10.8 and 10.5 years 69% remitting phase, 33% relapsing phrase, 21% SP; McDonald 2010 criteria | Decreasing EDSS score and MSSS | 43 cases, 34 controls | Case-control ANOVA | 1,25(OH)2D, 25(OH)D, Vitamin D-binding protein | N/A | Negative correlation between 25(OH)D and EDSS (r = -0.53, p < 0.01) | 25(OH)D levels in SPMS patients were decreased compared with R-R patients at remitting phase (p < 0.01); serum 25(OH)D correlates negatively with disease severity in R-R in the remitting phase and SP MS
Shahbeigi, 2013^86^ concurrent | Iran | Neurology clinic patients, 76% women, mean age 34 (SD 9.1), mean disease duration 6 years (5.14) Mild (73%), moderate (11%), and severe (16%) MS; mean EDSS score 2.76 (SD 1.93); McDonald 2005 criteria | EDSS score | 98 | Cross-sectional Correlation | 25(OH) Vitamin D3 concentration | N/A | Significant inverse correlation between EDSS and vitamin D level (r = -0.168, p = 0.049)
Smolders, 2008^90^ concurrent | The Netherlands | Outpatient clinic patients, 75% female R-R 47%, SP 32%, PP 18%, unknown 3%; McDonald 2001 criteria | EDSS score | 267 | Cross-sectional T test, Mann-Whitney U test, linear regression model, poisson regression model | 25(OH)D serum levels, 1,25(OH)2D | Sex, age, disease course (years) | Raw 25(OH)D levels correlated negatively with EDSS, there was no association between EDSS score and raw 1,25(OH)2D levels (p = 0.065); when vitamin D levels were tested as predictors of EDSS score, only the adjusted 25(OH)D level was an independent predictor, when the levels were considered as dependents of disability, only 25(OH)D was independently predicted by EDSS score (OR-3.155, CI -4.936, -1.374); 1,25(OH)2D level was not dependent upon disability
Soilu-Hanninen, 2008^91^ prospective | Finland | MS patients, mean age 34.1 (SD 1.5 years), mean time from the diagnosis of definite MS 5.6 years (range 6-15 years); healthy laboratory personnel living in the same area Form N/A, Mean EDSS 2.4 (range 0-5); criteria N/A | EDSS progression during 1 year | Treatment 23, Control 23 | Case-control Logitudinal analysis | Vitamin D (25(OH)D) level | Grouped by winter, spring, summer, and autumn serum 25(OH)D levels | No correlation between vitamin D nutrition and EDSS progression (p = 0.07)
Sternberg, 2013^95^ retrospective | US | MS patients: 75.7% female, mean age 55.6 (SD 11.5) years, mean disease duration 19.0 (SD 9.8) years 61% R-R, 31.6% SP, 7.4% PP; EDSS 4.1 (SD 2.2); criteria N/A | EDSS, MSSS score | 206 | Case control Regression analyses | Vitamin D3 plasma level | Cardiovascular drugs, smoking | Vitamin D level was inversely associated with EDSS (p = 0.05) and MSSS (p = 0.04)
Thouvenot, 2014^100^ concurrent | France | Files from MS clinic, age 45.3, 12.1 average years of disease, 72% women PP, SP, R-R; McDonald 2005 criteria | EDSS score | 181 | Other retrospective cohort analysis Kruskal-Wallis to compare vitamin D levels between MS types, Wilcoxon test comparing vitamin D levels in different origins | 25(OH)D plasma level | N/A | Vitamin D level associated with EDSS score in bivariate model OR = 2.87 (p = 0.0012)
Van der Mei, 2007^103^ concurrent, retrospective | Australia | Recruitment at local MS societies, eligible cases had cerebral MRI abnormalities and clinically definite MS RRMS, SPMS, PPMS; Poser criteria | EDSS score | 136 MS patients, 272 matched community controls | Case control ANOVA F test Linear regression | 25(OH)D status, time in the sun in summer and winter on leisure days in last 3 years, time in the sun in summer during work hours in the last year, past sun exposure, dietary intake last 12 months | Month serum sample was taken, duration of MS since first symptom | EDSS and 25(OH)D level correlation r = -0.38 (p < 0.0001); recent sun exposure was significantly associated with high EDSS (leisure r = 0.39, p < 0.01; during work hours r = 0.40, p < 0.01); no statistically significant correlation with past sun exposure or dietary intake
Weinstock-Guttman, 2011^108^ concurrent | US | MS patients mean age 46.6 (SD 10.6) years, disease duration 13.8 (SD 10.3) years, 71.9% female, 15.2% statin use 85.4% R-R, 11.8% SP, 2.8% PP; median EDSS 2.5, MSSS 3.5 (SD 5.43); McDonald 2010 criteria | EDSS and MSSS score, EDSS 4 or greater | 178 | Cross-sectional Stepwise regression | Vitamin D levels | Age, gender, race, statin use, lipid indicator variables | Deseasonalized 25-hydroxy vitamin D3 associated with MSSS (p = 0.021) but not included in EDSS prediction

Note: N/A not available, R-R relapsing-remitting, PP primary progressive, SP secondary progressive, vs versus

The 17 identified studies provided data on patients in different European countries, the US, Canada, Iran, Japan, Israel, and Australia. Several studies recruited patients through MS registries. Total sample sizes ranged from 46 and 2,837. The majority of studies were concurrent studies, measuring the current status of the proposed risk factor and the outcome of interest simultaneously. Four studies assessed retrospective data (ie, predicted outcomes from exposures in the past).^39,51,58,95^ Two studies were prospective studies^20,114^ reporting on the risk factor and outcome sequentially, with the exposure preceding the outcome measure.

Assessed potential risk factors (as reported) were serum or plasma 25(OH)D levels at the time of assessment, 25(OH)D levels in the summer and winter, 1,25(OH)2D, vitamin D-binding protein, vitamin D levels not further specified, dietary vitamin D intake, sun exposure in the summer, sun exposure in the winter, time in the sun on leisure and on work days, and the month of birth.

Several studies reported on the correlation between 25(OH)D levels and EDSS scores, either reporting the correlation coefficient, the p-value, or paraphrasing the association. No other specific risk factor (eg, sun exposure) and specific outcome (eg, MSSS score) combination was assessed in more than one study. Only one study reported on the change between relapsing-remitting MS to secondary progressive MS. Koch et al^51^ analyzed the month of birth and the time from MS onset to secondary progression in sample of patients with primary progressive or relapsing-remitting MS. Half the studies adjusted for potential confounders, such as age and duration of disease.

One of the prospective studies reported that 25(OH)D levels of 50nmol/L at up to 12 months predicted lower disability during the subsequent 4 years.^20^ The other prospective study reported a statistically non-significant correlation between vitamin D nutrition and EDSS progression, but it was unclear whether the study had sufficient power to detect an effect.^91^ The quality assessment of the two prospective studies is shown in the appendix. The study by Ascherio et al was a clinical trial sample,^20^ rather than derived from a large and broader in scope MS registry sample. The study by Soilu-Hanninen was very small (23 patients with MS) and may also not be a good representation of the population of interest.^114^

Another large group of studies reported on smoking and effects on disease progression, as documented in the next evidence table.

Table 2 Evidence for KQ1 (MS Progression Risk Factors): Smoking

ID Assessment timing | Region | Sample MS form | Predicted outcome | N | Design Analysis | Risk factors | Covariates | EDSS results | Other results
Healy, 2009^46^ retrospective | US | 1465 out of 1745 patients who completed questionnaire at MS center R-R (N = 1020), SP (N = 212), primary progressive (PP) (N = 63), progressive relapsing (PR) (N = 24), CIS (N = 106), unspecified demyelinating disease (N = 39), or suspected MS (N = 1); McDonald 2005 criteria | EDSS score, MSSS, time to conversion from R-R to SP, proportion of patients who progressed on EDSS after 2 years/after 5 years (increase in EDSS score) | 1465 | Cross-sectional Kruskal-Wallis, Wilcoxon, chi-square test, Cox proportional hazard model | Smoking history (smoking status, age of starting and quitting, average number of cigarettes smoked per day) | Age, disease duration from first symptom, gender | EDSS was significantly higher in current smokers (p < 0.0001) but not significantly different in ex-smokers (p = 0.22) compared to never smokers; EDSS was significantly lower in the light smoking group compared to the moderate smoking group (p = 0.040) and compared to the heavy smoking group (p = 0.025) | Conversion from R-R to SP occurred at faster rate in current smokers than never smokers (HR 2.50, CI 1.42, 4.41) but was similar in ex-smokers and in never smokers (HR 1.05, CI 0.59, 1.84); MSSS was significantly higher in the heavy smoking group compared to the light smoking group (p = 0.038) and the moderate smoking group (p = 0.048); probability of a PP course was higher among current smokers (OR 2.42; CI 1.09, 5.35) or ex-smokers (OR 1.91; 95% CI 1.02, 3.58) than never smokers
Hernán, 2005^47^ retrospective | UK | Individuals with a confirmed diagnosis of MS and 2 years or more of medical history prior to diagnosis available R-R; Poser criteria | R-R converting to progressive course (continuously worsening disability lasting 6 months or more as determined by 2 independent reviewers) | 201 | Case-control Cox proportional hazards regression | Current, past or never smokers; ever vs never smokers; according to medical records | Age at first symptoms, sex, first symptoms including motor deficits | | Incidence rate ratio of secondary progression was 3.6 (CI 1.3, 9.9) for ever smokers compared with never smokers; 80% of progression occurred by 4.6 years of follow-up in smokers and by 5.3 years in nonsmokers
Jansons, 2011^48^ retrospective | US | Patients with progressive MS Established progressive MS; criteria N/A | Time to progression from onset of MS in patients with relapsing-remitting MS; age at progression onset; time to EDSS 6 after progression onset | 756 | Cross-sectional Cox regression | Smoking (ever vs never; current vs previous; higher vs lower than mean pack-years) | Gender, age, number of 1st two year relapses, immune-therapy, PPMS vs SAPMS vs SPMS, post-progression relapses, symptoms at MS onset, CSF positivity | | More than 19 pack-years of smoking was independently associated with shorter time to progression (p = 0.015); smokers reached EDSS 6 ∼5 years earlier than never smokers (p < 0.001); smoking alone very strongly predicts an earlier onset of progression and disability after progression in MS
Koch, 2007^52^ retrospective | The Netherlands | Patients in MS database, definitive MS meeting Poser criteria Benign relapsing-remitting, R-R, SPMS, PPMS; Poser criteria | Benign relapsing-remitting, R-R, SPMS, PPMS; age at onset of SP, age at onset of PP disease; time from disease onset to EDSS 4, time from disease onset to EDSS 6; EDSS score | 364 | Case-control Conditional logistic regression and Cox hazard ratio | Smoking history: current status, starting and quitting dates, nonsmoking periods, number of cigarettes smoked, number of smoked pack-years before and after onset | Gender | No significant differences in the time to EDSS scores 4 and 6; total pack-years were not significantly correlated with EDSS in the total sample but in women (r = -0.16, p = 0.01) | In patients with PPMS, none of the variables had a significant effect on the age of progression
Maghzi, 2011^59^ retrospective | Iran | Patients from MS registry; smoking group: 78.5% female, mean age 32.75 (SD 8,68) years, mean age at onset 27.42 (SD 7.91) years; control group: 46.5% female, mean age 32.86 (SD 9.65) 83.2% R-R, 2.9% PP, 13.9% SP course in the smoking group; McDonald 2005 criteria, McDonald 2001 criteria | Progression (EDSS/disease duration) | 516 | Cross-sectional Conditional logistic regression | Ever/never smoker, smoking history, smoking duration, pack-years smoked | Age, gender | No difference in disease progression (EDSS/ disease duration) between smokers and nonsmokers (0.54, SD 0.42 vs 0.49, SD 0.48) in male patients
Manoucherhrinia, 2013^61^ retrospective | UK | Patients registered in MS specialist clinic database, 270 male, 625 female, mean age 49 years, mean duration of illness 17 years CIS, suspected MS, R-R, SP, PP; Lublin & Reingold criteria | Reaching EDSS 4, reaching EDSS 6 | 895 | Cross-sectional Linear regression, Cox proportional hazard regression model | Smoking status (nonsmoker, stopped before onset, stopped after onset, current smoker) | Sex, onset age, use of DMT, initial course (R-R, PP) | RR of reaching EDSS 6 was higher in smokers compared to nonsmokers; risk of reaching EDSS 4 and 6 in ever-smokers vs never-smokers was 1.34 (CI 1.12,1.60) and 1.25 (CI 1.02, 1.51); current smokers showed 1.64 (CI 1.33, 2.02) and 1.49 (CI 1.18, 1.86) times higher risk of reaching EDSS 4 and 6 compared with nonsmokers; ex-smokers had a significantly lower risk of reaching EDSS 4 (HR 0.65, CI 0.50, 0.83) and 6 (HR 0.69, CI 0.53, 0.90) than current smokers, and there was no significant difference between ex-smokers and nonsmokers in terms of time to EDSS 4 or 6 | No association between smoking status and PP vs R-R type at onset
Pittas, 2009^76^ prospective | Australia | Patients with MS, female 69.2%, mean age 48.2 years (SD 11.4), median age of MS onset 33.5 years, mean disease duration 14.1 (SD 10.3) years R-R at cohort entry 75%; mean EDSS 3.7 (SD 2.3); Poser criteria, McDonald criteria | MS progression (MS Severity Scale [MSSS]) | 203 | Experimental Mixed effects linear regression | Pack-years smoked in the past 6 months at entry, ever smoker, total pack-years prior to MS, pack-years from onset, current smoker | Entry MSSS and EDSS, age, gender, IMT use, education level, and month of review | | Cumulative pack-year smoked after cohort entry was associated with an increase in longitudinal MSSS (p < 0.001)
Roudbari, 2013^115^ retrospective | Iran | Patients registered in the MS Society (Guilan, Iran) database; mean age 34.8 (SD 9.5) years, 74% female, mean age at disease onset 1.7 (SD 2.3) years, 14% smokers, 86% nonsmokers R-R 64%, SP 36%; McDonald 2005 criteria | Risk of progression | 524 included, 400 responded | Cross-sectional Cox regression | Smoking (pack-years smoked; 20 cigarettes smoked per day for 1 year = pack-year; nonsmokers vs < 10 pack-years vs > 10 pack-years) | Age on disease onset, number of relapses per year, gender | | Compared with nonsmokers, current smokers who continued smoking after MS diagnosis and patients who started smoking after MS diagnosis showed a RR of 2.43 (CI 1.2, 4.8; p < 0.001) and RR 3.55 (CI 1.3, 9.2; p = 0.007) for MS progression; HR for smokers vs nonsmokers was 2.25 (CI 1.3, 3.99; p = 0.004); risk of SP was 2.43 times higher (CI 1.28, 4.6; p = 0.007) for greater numbers of cigarettes smoked per day vs nonsmokers
Sundström, 2008^97^ prospective | Sweden | Respondents MS epidemiological survey and interviews, 64% female R-R, SP, progressive from onset; criteria N/A | Progressive disease (PP, SP, or progressive relapsing) determined during interview, neurological exam, and medical records; progressive disease from onset, conversion to progressive disease (R-R, SP), time to progressive disease based on EDSS | 122 | Cross-sectional Multivariate Cox regression | Self-reported smoking habits; ever smoker (had to have started before MS onset to be included), never smoker; early start (15 or younger) or later start | Gender, age at disease onset, relapsing-remitting MS cases | | After a median of 6 years disease duration, progressive disease was significantly more likely to occur in ever smokers compared to never smokers (p = 0.006); progression was most likely in patients who started smoking early compared to later (p = 0.005) or never smokers (p < 0.001); cases with late disease onset had 3x higher risk and ever smokers had 2x as high a risk for progression
Tepavcevic, 2010^112^ prospective | Serbia | Patients with MS, age 18-60 years EDSS < 8; McDonald criteria | EDSS score | 98 | Prospective followup T-test, linear regression | Cigarette smoking status at baseline | Baseline EDSS, gender | The baseline smoking status showed independent predictive value on development of physical disability (p = 0.001)
Zivadinov, 2009^111^ retrospective | US | Patients with MS at MS center with MRI exam, age 18-80 years, mean age 44 (SD 10.2), mean disease duration 12.1 years (SD 9.1), 93% white, 6% black; 79% female R-R: 68.6%, CIS: 5.7%, SP: 22.9%, PP: 2.8%; criteria N/A | EDSS score | 368 | Cross-sectional Polytomous universal model ordinal regression method | Smoking: never-smoker, ever-smoker, active smoker; mean duration; average number of packs per day | Age, disease duration, treatment duration | Median EDSS for the ever-smokers was 3.0 compared with 2.5 for the never-smokers; association of EDSS score with never-smoker/ever-smoker status (p = 0.004)

Notes: N number of participants, N/A not available, SD standard deviation, R-R relapsing-remitting, PP primary progressive, SP secondary progressive, RR relative risk, vs versus

We identified 11 studies that exclusively evaluated the effect of smoking on disease progression. Studies from the US, different European countries, Iran, and Tasmania contributed research. All but 3 studies were retrospective analyses. Participants were recruited at MS centers and registries. The number of included participants ranged from 98 to 1,465.

Specific assessed risk factors were: current smoking status; smoking status as baseline; age of starting and quitting; early (15 years or younger) or later smoking start; number of cigarettes smoked per day; current, past, or never smokers; ever versus never smokers; number of cigarette pack-years in total; pack-years smoked in past 6 months; smoking status before and after onset of MS; nonsmoking periods; and smoking duration in years. Information came from self-reported survey data or medical records. All studies used multivariate methods controlling for demographic and disease characteristics.

Studies used a range of outcome predictors, assessing continuous outcomes, dichotomous status variables, and time to event data. The individual measures were EDSS scores, MSSS scores (measure of rate of disease progression, standardized for disease duration), EDSS score divided by disease duration, time to conversion to secondary progression from onset, time from disease onset to EDSS 4, time to EDSS 6, reaching EDSS 4 during study period, reaching EDSS 6, experiencing progression, age at onset of secondary progression, and proportion of patients who progressed on EDSS after 2 years/ after 5 years (increase in EDSS score).

Three prospective studies were identified. All reported a statistically significant effect of smoking on MS but reported on different outcome measures.^76,97,112^ The detailed quality assessment of the prospective studies is shown in Appendix C. Two of the studies did not indicate major flaws. One was published as an abstract only and lacked detail.

The following evidence table shows studies that investigated childbirth-related factors such as the use of epidural analgesia during childbirth.

Table 3 Evidence for KQ1 (MS Progression Risk Factors): Childbirth-associated Factors

ID Assessment timing | Region | Sample MS form | Predicted outcome | N | Design Analysis | Risk factors | Covariates | EDSS results | Other results
Confavreux, 1998^30,116^ prospective | Europe, multiple countries | Women had MS before pregnancy and were pregnant, referred by European neurologist; duration of MS before pregnancy 6 years, age at beginning of pregnancy 30 96.6% R-R, 3.14% SP; mean EDSS at baseline 1.32; Poser criteria | EDSS or DSS | 254 | Time series Logistic regression | Epidural analgesia, breast feeding | Age, duration of disease, occurrence of relapses before and during pregnancy | | No acceleration of the progression according to use of epidural analgesia (p = 0.66) or breastfeeding (p = 0.27); same finding 2 years post-partum
Gava, 2014^40^ retrospective | Italy | Women with MS at an academic medical center SP and R-R; McDonald 2010 criteria | EDSS score | 174 | Cross-sectional Logistic regression analysis | Oral contraceptives use | Age, duration of disease, age of menarche, use of DMT, parity | Ever users of combined oral contraceptives had lower EDSS scores compared to never users (p = 0.044)
Lu, 2013^57^ retrospective | Canada | Female MS patients with live births, British Columbia Perinatal Database Registry, mean age 32 years 99% relapsing-onset, 1% PP; Poser criteria, McDonald 2005 criteria | EDSS 1-1.5 vs 2-2.5 vs 3 or higher | 431 | Cross-sectional Multivariate models | Obstetrical epidural and spinal anesthesia use during delivery | Age, parity, comorbidities, mode of delivery, birth weight, gestational age in weeks | EDSS was not associated with use of either type of anesthesia (p > 0.1)
Pastò, 2012^72^ prospective | Italy | Women with pregnancies between 2002 and 2008 in 21 MS centers, mean age at conception 31.8, mean age at onset 24.7, mean disease duration at conception 7.1 years Form N/A, mean EDSS at conception 1.5 (SD 1.0); McDonald 2010 criteria | Progression on EDSS | 415 | Cross-sectional Multivariate analysis | Epidural analgesia delivery, cesarean delivery | Age at MS onset, age, disease duration, EDSS at conception, DMT before pregnancy, number of relapses in year before pregnancy / during pregnancy, exclusive breastfeeding | Epidural analgesia delivery and cesarean delivery were not associated with disability progression after delivery
Sena, 2012^85^ retrospective | Europe | Female MS patients registered with hospital,with R-R MS, median disease duration 6.2 (SD 5.1) years, never-users vs past-users vs after-users: mean age 37.3 (SD 10.2) vs 38.6 (SD6.8) vs 32 (SD6.6) years, mean age at disease onset 29.9 (SD 9.8) vs 34.6 (SD R-R; McDonald 2005 criteria | EDSS, MSSS scores; benign course (MSSS < 2.5) | 132 (53 never-users, 26 post-users, 54 after-users) | Cross-sectional Multivariate linear and logistic regression | Oral contraceptive use | Age, gender, smoking, childbirths, age at disease onset, disease duration, relapse rate, age of menarche, age at onset of OC use, OC use duration | After-user patients had lower EDSS and MSSS scores than never users (p < 0.001, p = 0.002) and past users (p = 0.015 and p = 0.002) | Patients who took oral contraceptives after disease onset were more likely to have a more benign disease course (MSSS < 2.5) than never / past users (OR: 2.97; CI 1.24, 6.54; p = 0.011)

Notes: DMT disease modifying treatment, N number of participants, N/A not available, SD standard deviation, R-R relapsing-remitting, PP primary progressive, SP secondary progressive, vs versus

We identified 5 studies reporting on pertinent risk factors. Study sample sizes in the studies varied widely, ranging from 174 to 2,105 included women. Studies used different outcomes measures: EDSS, DSS, or MSSS scores. One study included only patients with relapsing-remitting MS. It predicted EDSS and MSSS scores and reported on the odds ratio of having a more benign disease course defined as MSSS below 2.5.^85^

The studies evaluated a number of potential risk factors that may be associated with MS progression: epidural and/or spinal analgesia during delivery, breast feeding, use of oral contraceptives, and cesarean delivery. All studies adjusted for covariates in the analyses, in particular the age at the time of the first child and age at MS onset.

Three studies were retrospective analyses but 2 studies assessed women at the time of pregnancy and followed them for a number of years.^30,72^ The quality assessment of the prospective studies are shown in the appendix. The main source of potential bias was confounding due to selection bias. It is possible that participants self-selected the exposure or intervention, such as breast feeding, because of their EDSS scores. Hence studies may show reverse causality with EDSS scores (the outcome) influencing the variable assessed as the risk factor.

We also identified studies that exclusively reported on diet and its effects on disability and progression of MS, as documented in the following evidence table.

Table 4 Evidence for KQ1 (MS Progression Risk Factors): Diet

ID Assessment timing | Region | Sample MS form | Predicted outcome | N | Design Analysis | Risk factors | Covariates | EDSS results | Other results
Aupperle, 2005^21^ concurrent | US | Patients with MS, 84% female R-R; criteria N/A | EDSS | 38 | Case-control Analysis N/A | Red blood cell fatty acids, dietary fatty acids intake | N/A | None of the fatty acids were related to disability
Foster, 2012^38^ retrospective | US | MS patients, mean age 47.8 (SD 12.5) years, mean disease duration 15.2 (SD 10.5) years, median EDSS 3.0 (SD 4.0) 93.5% Caucasian American, 4.5% African American, and 5% other races, 76% female 66.2% R-R, 22.4% SP, 7% relapsing SP, 4.4% PP or primary relapsing; McDonald 2001 criteria | EDSS and MSSS scores | 272 cases, 151 controls | Cross-sectional Regression analyses | Duration of alcohol consumption after MS diagnosis 15 years or fewer (compared to no consumption of alcohol or consumption for > 15 years) | Age, age of onset, sex, disease duration | EDSS scores were lower in patients who had consumed for 15 years or fewer after MS onset compared those who did not consume alcohol or consumed it for > 15 years; pattern of nonlinear dependence suggests that moderate duration of alcohol use does not have adverse effects
Kurtzke, 1973^54^ retrospective | US | Men first diagnosed with MS in US Army hospitals during World War II Form N/A; Schumacher criteria | DSS score change (better, same, worse after hospitalization) | 517 | Other Count comparison | Diet | N/A | | Diet: 28% better, 56% the same, 16% worse; patients with hospital routine without specific treatments: 19% better, 74% same, 8% worse.
Plow, 2012^77^ concurrent | US | N/ARCOMS registry, 292 respondents out of 1000 randomly selected surveyed patients, 79.7% female, average duration since diagnosis 15 (SD 8.30) years 63% R-R, 20% SP, 8.1% PP, 6.6% progressive relapsing MS; criteria N/A | Type of MS (R-R, progressive, unknown) | 292 | Cross-sectional Logistic regression | Healthy nutritional behavior indicator defined by whether participants answered 4 out of 5 questions with the response of “often”: 1) make good food choices, 2) eat 5 servings of fruits and vegetables a day, 3) limit fat intake, 4) read labels, 5) eat regularly | Gender, optimism/pessimism, BMI, physical activity, emotional self-management, communication with physician | | Nonsignificant correlation type of MS-nutritional behavior (p = 0.38)
Swank, 1990^98,117^ prospective | US, Canada | Patients who maintained contact with MS clinic Form N/A, minimum, moderate, and severe disability; other criteria | Average worsening in disability grade, percentage of deaths due to MS | 144 | Case series t-test | Good dieters (fat consumption = < 20 g/day) vs poor dieters (consumption > 20 g/day), period checks of eating habits (presumably) self-reported | N/A | | In each of the disability groups the average worsening in disability grade and the percentage of deaths of the poor dieters significantly exceeded those of the good dieters; greatest difference occurred for minimum disability at study entry (p < 0.0001)

Notes: N number of participants, N/A not available, N/ARCOMS North American Research Committee on Multiple Sclerosis, SD standard deviation, R-R relapsing-remitting, PP primary progressive, SP secondary progressive, vs versus

We identified 4 studies that exclusively looked at dietary behavior. All studies were conducted in the US or the US and Canada.

One study reported concurrent data, meaning current dietary fatty acid intake, in patients with relapsing-remitting MS. The study, published as a conference abstract, lacked detail but stated that none of the assessed fatty acids were related to disability.^21^

Two studies were retrospective analyses.^38,54^ One reported on the duration of alcohol consumption after MS diagnosis. The other focused on men on active duty in the US Army and reported on the disease course for patients that were put on a specific diet in the hospital, compared to patients without administration of a specific therapy.^54^ The study did not report a statistical analysis but, applying Fisher's exact test to the raw data, we find that the difference between groups was not statistically significant. No information was available on the specific diet and approaches may have varied across patients and hospitals.

A fourth study reported on the Swank diet in multiple publications.^98,118,119^ The prospective study compared “good dieters,” meaning people with fat consumption of 20g per day or less, and “poor dieters” who exceeded the fat consumption limit. Patients who were given the diet advice were followed for 34 years. The study reported that in each of the disability groups, the average worsening in disability grade and the percentage of deaths of the poor dieters significantly exceeded those of the good dieters. The detailed quality assessment of the study is shown in Appendix C. The main concern is the ascertainment of the risk factor, which in this case is the compliance of the participants with the diet and self-reports that determined the classification into good or poor dieters.

A small group of studies exclusively reported on exercise behavior as shown in the following evidence table.

Table 5 Evidence for KQ1 (MS Progression Risk Factors): Exercise

ID Assessment timing | Region | Sample MS form | Predicted outcome | N | Design Analysis | Risk factors | Covariates | EDSS results | Other results
Marrie, 2009^62^ retrospective | US, Canada | N/ARCOMS questionnaire respondents, 94.5% white, 75.8% women, mean age 52.7; mean age at onset 31.2, mean age of diagnosis 31.2, mean disease duration 21.5 Form N/A, PDDS mild disability 35.4%, moderate disability 11.95, severe disability 52.7%; criteria N/A | PDDS category | 8983 | Cross-sectional Multivariate regression | Physical activity, leisure-time activity (scale from 1 = inactive to 4 = heavy activity) in the last year | Smoking status, physical activity level | | Physical activity decreased steadily with increasing disability
Milivojevic, 2013^64^ retrospective | US | MS patients, 65.1% female, mean age 38 (range 21-58), mean disease duration 5.4 years (range 1-16) Form N/A, mean EDSS 1.7 (range 0-5.5); neurological evaluation | EDSS score | 63 | Cross-sectional T-tests | Use of physical rehabilitation | N/A | Patients who used inpatient, outpatient, and home-based rehabilitation had higher levels of impairment compared to patients who were not rehabilitated (p = 0.002, p = 0.004, p = 0.0021)
Motl, 2012^68^ prospective, retrospective | US | MS patients recruited through National MS Society, mean age 45.9 (SD 9.6) years, mean disease duration 8.8 years (SD 7.0), median PDDS 2, 86.6% female, 91% Caucasian, well-educated R-R; criteria N/A | Progression in PDDS | 269 | Time series Latent growth curve modeling | Premorbid physical activity | Gender, age disease duration since diagnosis, disease-modifying therapies | | Premorbid physical activity predicts the linear change in disability scores (PDDS) (p < 0.005)
Shammas, 2014^87^ prospective | Germany | Patients with definite MS and EDSS < 5, 64% female, mean age 41 years (SD 9.3), mean disease duration 12.18 years (SD 10.67), recruited in MS clinic 8/11 R-R, 1/11 PP, 2/11 SP, mean EDSS 3.6 (SD 1.66); McDonald 2010 criteria | EDSS score | 11 | Other Correlation | Total number of steps taken during study period | Age, gender, weight, height, shoe sizes | Number of steps negatively correlated with EDSS score (r = -0.54, p = 0.01)
Stuifbergen, 2006^96^ prospective | US | Patients from MS Society patients and advertisments in rural newspapers, mean age 49.4 years, 83% women R-R, PP, SP, PR; criteria N/A | Incapacity Status Scale (ISS) scores | 611 | Time series Multivariate latent curve modeling | Exercise behavior (HPLP-II exercise/physical activity subscale) | Age, sex, years since diagnosis, residency type, attrition | | Exercise behaviors and functional limitations were negatively correlated (r = -0.34); time 1 exercise scores were negatively correlated with annual change rate in functional limitations (r = -0.17); increasing rates of change in functional limitations correlated with decreasing rates of change in exercise behavior (r = -0.25)

Notes: N number of participants, N/A not available, N/ARCOMS North American Research Committee on Multiple Sclerosis, SD standard deviation, R-R relapsing-remitting, PP primary progressive, SP secondary progressive, vs versus

The 5 studies addressing exercise were conducted in the US, US and Canada, and Germany. The number of included participants ranged from 11 to 8,983. The studies included retrospective and prospective analyses.

A large retrospective study used data from 8,983 survey respondents.^62^ It reported an association between self-reported physical activity in the last 12 months and disability measured with the Patient Determined Disease Steps (PDDS), indicating that physical activity decreased steadily with increasing disability. The PDDS is a self-report measure of disability using a scale of 0 (normal) through 8 (bedridden), developed as a surrogate for the EDSS. Another retrospective study assessed the use of physical rehabilitation and reported that patients who had used inpatient, outpatient, or home-based rehabilitation had higher levels of impairment compared to patients who were not rehabilitated.^64^

A very small, prospective study in 11 participants reported a negative correlation between objectively measured physical activity over one year and EDSS scores.^87^ No other data were reported that may inform the temporal association between the 2 variables, such as the effect of physical activity at baseline on MS progression.

A prospective study by Stuifbergen et al, on the other hand, assessed exercise behavior in a sample followed for 5 years. Exercise scores at the first assessment time point were negatively correlated (r = -0.17) with annual change rate in functional limitations due to MS (Incapacity Status Scale, ISS; self-reported degree of impairment).^96^ A prospective study by Motl et al^68^ reported that participants with higher premorbid physical activity levels reported less change in disability over time (PDDS scores) compared with those who reported lower premorbid physical activity.

The risk of bias evaluation for the prospective studies is shown in the Appendix C. The objectively measured study only included 11 patients and data were not prospectively analyzed.^87^ The other prospective studies were higher quality but neither reported on EDSS scores, the primary outcome of this review.

The next evidence table summarizes studies that addressed other exposures not captured in previous evidence tables, such as exposure to trauma.

Table 6 Evidence for KQ1 (MS Progression Risk Factors): Other

ID Assessment timing | Region | Sample MS form | Predicted outcome | N | Design Analysis | Risk factors | Covariates | EDSS results | Other results
Baghizadeh, 2013^22^ retrospective | Iran | Neurology and MS clinic-attending patients, 78% female, mean age 34 yrs, mean age of onset 24 yrs R-R, SP, PP; McDonald criteria | MSSS scores (chronic, mild-moderate, advanced-accelerated, aggressive-malignant disease severity) | 338 | Cross-sectional Ordinal logistic regression | Education | Unclear | | Education did not predict getting worse (p = 0.074)
Detels, 1982^35^ prospective | US | MS onset between Jan 1, 1960 and Dec 31, 1969, born in the US, white, residents in 1970 in either a low-prevalence (Los Angeles County, CA) or in a high-prevalence area (King and Pierce Counties, WA); LA: 67.7% female, WA: 74.8% female; mean age at onset 33.4 yrs Form N/A; Schumacher criteria | 3-point scale: 1) walking without aids; 2) walking with aids such as braces, crutches, or canes; and 3) restricted to wheelchair or to bed (self-reported) | 560 cases in LA, 326 cases in WA | Cross-sectional Multivariate regression | Geographic regions (high- vs low-prevalence area) | Age at onset, residence, sex, disability status at intake | | Progression to a non-ambulatory status or death was significantly greater among patients who lived in LA county (low-prevalence area)
Sibley, 1990^89^ retrospective | US | Patients in the community with clinically definitive MS, mean age 43 years, female to male ratio 1.6 to 1 Form N/A; Schumacher criteria | Mean increase in DSS/year | 170 MS patients | Other design Chi-square test | Trauma, different subtypes (dental procedures, minor surgery, major surgery, fractures, sprains, burns, head injuries, abrasions/lacerations/contusions) | N/A | | Peripheral trauma is not a risk factor for MS progression
Spitzer, 2012^93^ retrospective | Germany | Patients with definite MS attending a MS outpatient clinic, age 18-50 years, mean age 39.7, 73% women, mean MS onset 29.2 years, mean MS duration 10.5 years, mean relapse rate 0.66% 70% R-R, 7% PP, 23% SP, mean EDSS score 3.2; McDonald 2001 criteria, McDonald 2005 criteria | EDSS score, disease progression (EDSS scores divided by years of disease duration) | 234 with MS | Case-control Logistic and multiple linear regression | Self-reported childhood maltreatment (CTQ total score, emotional abuse, physical abuse, sexual abuse, emotional neglect and physical neglect) | Age, sex, education, current depression | | Childhood trauma was not associated with disease progression or EDSS
Tuzun, 2010^102^ retrospective | Turkey | MS patients with R-R or SP MS; earthquake victim vs control: 66.7% vs 58.8% female, mean age of onset 26.8 (SE 1.3) vs 24.8 (SE 1.2), 68.6% R-R, 31.2% SP, EDSS 3.09 (SE 0.3) (earthquake); 64.7% R-R, 35.3% SP, 3.01 (SE 0.4) (control); McDonal criteria | EDSS score | 82 | Cross-sectional Logistic regression | Earthquake experience | N/A | Comparable EDSS scores between groups after the earthquake
Vollmer, 2002^104^ retrospective | US | US Veterans and non-veterans from NARCOMS patient registry Relapsing, PP; criteria N/A | PDDS score | 2150 Veterans, 2107 non-VHA Veterans, 16119 non-veterans | Matched controls Paired t-test | VHA Veteran, non-VHA Veteran, non-veteran | N/A | | PDDS scores 5.0 in VHA, 4 in non-VHA Veterans, 3.6 in non-veterans (p < 0.001 VHA Veteran vs non-veteran)

Note: N number of participants, N/A not available, N/ARCOMS North American Research Committee on Multiple Sclerosis, R-R relapsing-remitting, PP primary progressive, SP secondary progressive, SD standard deviation, vs versus

We identified 6 studies that reported on unique risk factors of interest. Three were US studies, one was conducted in Iran, one in Turkey, and one in Germany. All but one were retrospective studies; one followed patients prospectively.^35^ Where reported, studies included a range of MS subtypes. The largest study compared 2,150 VHA Veterans with 2,107 non-VHA Veterans and 16,119 non-veterans.

In terms of risk factors, studies reported on education, peripheral trauma (eg, surgery, head injuries), childhood maltreatment, geographic regions with high or low MS prevalence, recent earthquake exposure, and being a VHA Veteran.

A prospective study reported that progression to a non-ambulatory status or death was significantly greater among patients who lived in LA county, a low-prevalence area for MS.^35^ The detailed risk of bias assessment for this study is shown in the appendix. Of note, the study measured disability status at follow-up by a self-administered mailed questionnaire; hence, the progression data are not based on physician assessments.

One study used a VA-relevant dataset and reported that VHA Veterans had higher PDDS scores than non-veterans.^104^

The other studies reported no associations between assessed predictors and outcome measures.

The last KQ1 evidence table summarizes all those studies that reported on more than one group of risk factor of interest for this review, for example studies reporting the effect of smoking and exercise.

Table 7 Evidence for KQ1 (MS Progression Risk Factors): Multiple

ID Assessment timing | Region | Sample MS form | Predicted outcome | N | Design Analysis | Risk factors | Co-variates | EDSS results | Other results
Bombardier, 2004^27^ concurrent | US | Survey respondents with diagnosis of MS by MRI, 77% female, mean age 48.7 years, mean EDSS 5.7, mean disease duration 11.8 years Form N/A; criteria N/A | EDSS score | 739 respondents (out of 1374 surveyed) | Cross-sectional T-test | Possible, current alcohol problems during preceeding month (4 items) vs no alcohol problems; drug or medication misuse during the past month (1 item) vs not | N/A | Respondents with possible alcohol-related problems (p = 0.001) and respondents with drug misuse (p < 0.05) had lower EDSS scores
D'hooghe, 2012^36,120-122^ retrospective | Belgium | Flemish MS Registry, relapsing vs progressive onset patients: mean age 50.3 vs 58.6, mean age onset 31.5 vs 37.3, mean disease duration 18.8 vs 21.4, female 75.6% vs 62.2%, 33.3% relapsing onset, 34.9% progressive onset, EDSS >= 6 35.9% vs 80%; Poser criteria | Time from onset or from birth to sustained EDSS 6 | 1431 respondents (out of 3320 invited); 704 with EDSS 6 or more | Cross-sectional Kaplan-Meier survival and Cox proportion al hazard regression | Alcohol, coffee, and fish consumption (compared to no consumption); smoking; sun exposure in summer (hours daily), sun exposure in winter, sun exposure compared to peers, sunscreen/protect ion, working place (inside, both, outdoors); age at starting oral contraception, duration of oral contraceptive intake; health promoting lifestyles profile II (HPLP total score, health responsibility, physical activity, nutrition, spiritual growth, interpersonal relationships, stress management) | Gender, age at MS onset, IMT use | In relapsing MS, alcohol, wine, coffee, and fish consumption were associated with a reduced risk to reach EDSS 6; in progressive onset MS, all n.s. Smoking was associated with an increased risk to reach EDSS 6 in relapsing onset MS; in progressive onset MS, all n.s. except for type of fish (fatty fish associated with increased risk to reach EDSS 6 compared to lean fish). In relapsing onset MS, respondents reporting equal or higher levels of sun exposure than peers had a decreased risk of reaching EDSS 6 In progressive onset MS, the use of oral contraceptives was related to an increased risk. For relapsing onset, HPLP (p = 0.030), health responsibility (p = 0.218), physical activity (p < 0.001), and nutrition (p < 0.001) were predictive of time from onset to EDSS 6 but not spiritual growth (p = 0,048); time from birth analyses showed physical activity and nutrition to be significant (p < 0.001); for progressive onset, all n.s.
Goodin, 1999^43^ concurrent | US | Survey respondent with definite MS, 78.6% female, 92.5% Caucasian, 2% African American, 2.5% Asian, 3.0% Hispanic, mean age 48.1, mean age at MS onset 31.1, mean duration of symptoms 17.1 years 57.8% R-R, 22.6% SP, 20.1% PP; mean EDSS 4.8 (SD 2.3); diagnosed by a physician, any criteria | EDSS score | 168 | Cross-sectional Multiple regression | Exercise, consumption of alcohol (5-point scale from never to daily), insurance coverage, physical therapy, getting a 2nd opinion, being happy with medical care or coverage, being denied medical coverage or treatment, other dietary factors | unclear | Exercising (p = 0.001) and consumption of alcohol (p < 0.001) associated with lower EDSS scores; medical insurance coverage (p < 0.001) and physical therapy (p < 0.001) associated with higher EDSS scores; getting a second opinion, being happy with or being denied medical coverage, other dietary factors not associated with EDSS (p > 0.05)
Lauer, 1992^55^ retrospective | Germany | MS patients, 64.1% female 64.2% benign, 35.8% malignant MS | MS patients with benign (DSS = < 2.0 after 11 or more years' duration) vs malignant (DSS > = 7.0 after less than 16 years' duration) course | 81 (52 benign, 29 malignant) | Cross-sectional Logistic regression | Ether anesthesia, brain trauma, vaccination (poliomyelitis, diphtheria, tetanus, influenza), childhood diet breast fed, diet rich in animal fat, predominantly butter, domestic slaughtering, milk daily, unpasteurized milk, 3 or more eggs per week, animal brain, often brain sausage; childhood animal exposures (dog, cat, bird, pig , rats, mice, other rodents, cattle); animal exposure within 5 years before onset (dog, cat, bird, domestic rodents, cattle, pigs); childhood coal heating, wood heating, humid flats, no sewage system, no piped water; frequent environments (farm, industrial plant, fields, meadows/pastures, natural waters, forest, close to wood) | Covariates | Associated with benign course: milk daily (OR 3.03, p = 0.03), grew up with chickens (OR 2.77, p = 0.03), frequent environment meadows/pastures (OR 3.88, p = 0.007), close contact to wood (OR 3.31, p = 0.017); not associated with ether anesthesia, vaccination (poliomyelitis, diphtheria, tetanus, influenza), brain trauma, childhood diet breast fed, diet rich in animal fat, predominantly butter, domestic slaughtering, unpasteurized milk, 3 or more eggs per week, animal brain, often brain sausage, dog, cat, bird, pig , rats, mice, other rodents, cattle, within 5 years before onset dog, cat, bird, domestic rodents, cattle, pigs, childhood coal heating, wood heating, humid flats, no sewage system, no piped water, other frequent environments (farm, industrial plant, fields, natural waters, forest)
Mandia, 2014^60^ retrospective | Italy | MS patients mean age 45 (SD 11.0 ) years, disease duration 13.6 (SD 9.1) years Form N/A, mean EDSS 3.0 (SD 2.4), MSSS 3.2 (SD 2.6); McDonald 2001 criteria | MSSS score, MSSS 1 or less (mild) vs MSSS 6 or more (severe) | 131 | Cross-sectional Multiple linear regression | Smoking (ever, never, ex, current smoker, active/passive exposure), sunlight exposure (frequent vs rare, > 2h/day vs < 2h/day, sunscreen use), diet (vegetarian, egg consumption, fish consumption, consumption of dairy products, liver consumption, vitamin supplementation, fortified foods) in previous 2 years | Age, sex, covariates | | Severe MS was predicted by vitamin D (p = 0.001) and sun exposure (p = 0.005) but not smoking or diet
McDowell, 2011^63^ retrospective | US | Patients with progressive MS, mean age 61 (SD 9.6), between 18 and 65 years old at time of onset, 77% male, born and raised in the USA, registered in the VHA Multiple Sclerosis Surveillance Registry Progressive MS (progressively worsening from symptom onset with or without any recovery from symptoms later in the course), PP, and progressive relapsing MS; McDonald criteria 2001 | Time to PDDS 8 | 219 | Other Kaplan-Meier analysis, log rank tests, Cox proportion al hazards models | Average fall/winter sun exposure before MS onset, cod liver oil intake at ages 6-15, fish consumption at ages 6-15 | Age at symptom onset, MS subtype, onset symptoms, demographics, mononucleosis before symptom onset, smoking before disease onset, type of skin | | Median time from disease onset to PDDS 8 was 20 years (CI 16, 29) for low average fall/winter sun exposure compared to 29 years (CI 14, 42) for higher exposure; fall/winter sun exposure HR 2.13 (CI 1.20, 3.78, p = 0.01), cod liver intake HR 0.44 (CI 0.20, 0.96; p = 0.04), fish consumption HR 0.79 (CI 0.45, 1.41; p = 0.43)
Mowry, 2012^69^ prospective | US | EPIC cohort (5-year longitudinal MS cohort), white MS patients over 18, with EDSS score < 8 from MS center MS or CIS; McDonald 2001 criteria McDonald 2005 criteria | EDSS score | 469 | Time series Multivariate regression | 25 hydoxyvitamin D level, smoker at baseline (5 years earlier) | Age, sex, ethnicity, DMT | EDSS was not associated with smoking at baseline (IRR 0.09, p = 0.49) but each 10 ng/mL higher vitamin D level was associated with lower subsequent disability (IRR -0.047, CI -0.091, -0.003; p = 0.037)
Teter, 2008^99^ retrospective | US | Female MS patients age 45 and older, NYSMSC registry, mean age 54.2 (SD 7.3), mean disease duration 18 (SD 10.8) years 48% progressive disease at enrolment; criteria N/A | EDSS > 6 | 2935 | Cross-sectional Logistic regression | Educational attainment, sun exposure | Age, disease duration, MS type | Lower educational attainment (OR 1.5, 95% CI 1.2, 2.8) and less sun exposure (OR 1.8, 95% CI 1.2, 2.8) predict EDSS > 6
Wallin, 2015^105^ retrospective | US | Gulf War-era MS cohort with US military service between 1990-2007 Form N/A; criteria N/A | Progression to DSS 6 and DSS 7 | 2691 | Cross-sectional Cox proportion al hazard model | Geographic location and occupational status at entry to the military, deployment to a war theater | | | Deployment to a war theater , geographic location and occupational status at entry to the military were not predictors of progression to DSS 6 and DSS 7
Weiland, 2014^106,123,124^ retrospective, concurrent | Australia, US, Europe | Internet survey, adults diagnosed with MS by a physician Form N/A, physician diagnosis | PDDS converted to normal/some disability, gait/ cane disability, major mobility support | 2469 | Cross-sectional Multiple regression | Alcohol (frequency of alcohol use, amount; non-drinker, low level vs high level of consumption, binge drinking; moderate drinking [up to 30g/day for women, up to 45g/day for men] vs low or no alcohol consumption); smoking (current, former, or never smoker; frequency, time since quitting; physical activity; meditation practice, frequency | Gender, age | | Disability associated with moderate alcohol consumption (p < 0.001) and smoking status (p < 0.001); being a current smoker increased odds of requiring major mobility support (OR1.9, CI 1.44, 2.5; p < 0.001), being a former smoker associated with increased odds of 1.24 (CI 1.0, 1.5, p = 0.23) compared with never smokers. Those with higher disability had a lower level of physical activity and vice versa (p < 0.001) No association between those who did and did not meditate in PDDS scores but significant association with frequency of meditation and PDDS (more-disabled respondents were more likely to meditate, p < .001)

Note: IRR incidence rate ratio, N/A not available, n.s. not statistically significant, NYSMSC New York State Multiple Sclerosis Consortium, R-R relapsing-remitting, PP primary progressive, SP secondary progressive, RR relative risk, vs versus

The 10 studies that each addressed multiple risk factors of interest were 6 US studies, one which included the data from the Flemish MS registry, one study which was conducted in Germany, one in Italy, and one study which reported on an internet survey which international responders.

The studies addressed a wide range of potential risk factors such as alcohol, wine, coffee, fish, cod liver oil, and fat consumption. Studies also addressed health-promoting nutrition and other dietary factors; alcohol-related problems, drug misuse, smoking; vitamin D levels, sun exposure; oral contraceptive intake; physical activity; meditation practices, spiritual growth; interpersonal relationships; and stress management behaviors. Some studies associated MS progression with insurance coverage and treatment-associated factors; latitude and geographic location; and deployment to a war theater.

Three studies primarily reported on concurrent data^27,43,106^ (that is, linking current behavior such as current alcohol intake to EDSS scores). Most studies assessed the effects of prior events, exposures, or behaviors in retrospective studies.^36,55,63,105,106 60,99^ The retrospective study by D'hooghe was based on a 2009 survey of people registered in the Flemish MS society, and the data were reported in multiple publications focusing on the effects of alcohol, coffee, fish, and smoking;^36^ sunlight exposure;^120^ and menarche, oral contraceptives, and self-reported health promotion behaviors.^122^ A German study assessed a catalogue of potential risk factors, ranging from exposure to vaccines, childhood diet, exposures to pets and livestock, and environmental factors such as living near an industrial plant.^55^

One prospective study addressed vitamin D levels and smoking. The longitudinal US study reported that EDSS scores were not associated with smoking at baseline but each 10ng/mL higher vitamin D level was associated with lower subsequent disability.^69^ The detailed risk of bias assessment for this high-quality study is documented in Appendix C.

### Summary of Findings and Quality of Evidence

We identified a large number of studies reporting on potential modifiable risk factors for MS progression. However, studies assessed very specific risk factors (eg, vitamin D serum level, sun exposure in the summer 2 hours or more daily, etc) and predicted very specific outcomes (eg, EDSS scores, time to reach EDSS 6, etc). The following summarizes the available evidence for individual risk factors across all identified risk factor studies.

#### Vitamin D

Vitamin D and sun exposure-associated variables have been addressed in a large number of studies; however, the risk factor analyses used many different approaches, as documented in the evidence tables (see Table 1 and Table 7). The following figure summarizes the correlation between EDSS scores and the physiological vitamin D level of participants. The figure shows a risk factor and outcome measure that was reported in multiple studies that all reported a correlation as the measure of association or allowed computing a correlation from the reported data.

Figure 2 Correlation between EDSS Score and Vitamin D Level

Eleven included studies reported a correlation between vitamin D levels and EDSS scores. Across all available data, there was a weak negative correlation of -0.22 (CI -0.32, -0.12; 11 studies) indicating that lower vitamin D levels are associated with higher EDSS scores. All individual studies suggested the same direction of effects but not all were statistically significant and there was evidence of heterogeneity (I^2^ 66%). We also identified evidence of publication bias (regression test p = 0.045, rank test p = 0.087). Using the trim-and-fill method of correcting for potentially missing studies, the estimate was slightly lower but still statistically significant (r = -0.20; CI -0.29, -0.11).

Eight data points in the meta-analysis came from concurrent data analyses, assessing current vitamin D level and EDSS scores at the time of data assessment. One retrospective chart review also reported an association.^95^ Of the 2 included prospective studies, one highlighted that there was not a statistically significant negative correlation between vitamin D nutrition and EDSS progression.^91^ However, the finding is likely to be linked to the small sample size; the reported correlation is in range with other reported results seen in the forest plot. The other prospective study showed higher vitamin D levels to be associated with lower subsequent disability in a multivariate analysis.^69^

An additional prospective study assessing on vitamin D was identified that could not be added to the meta-analysis because it reported on other measures of association. The study reported that values greater than or equal to 50nmol/L at up to 12 months predicted lower EDSS scores (p = 0.004).^20^

The evidence suggesting a correlation between vitamin D levels and EDSS scores was downgraded to only moderate quality of evidence due to indirectness. For this systematic review, the correlation between the physiological measures of vitamin D serum or plasma level is an indirect outcome. The review evaluated patient-modifiable risk factors, such as exposure, intake, or behavioral risk factors. The meta-analysis shows a correlation between the physiological level and a progression measure and whether the physiological levels can be directly influenced by the participant is an unresolved question. We did not identify more than one study reporting on intake of vitamin D and a measure of MS progression.

#### Sun Exposure

Five studies reported on sun exposure and MS progression.^36,60,63,99,103^ All were retrospective studies. Four reported a negative association of sun exposure and MS progression or a positive association of increasing disability and reduced sun exposure. One reported an association in patients with relapsing onset MS but not in progressive onset MS. However, all studies used different assessment tools (EDSS, PDDS, and MSSS) and different predictors (time to sustained EDSS 6, time to PDDS 8, a score of MSSS 6 or above, odds of reaching an EDSS score greater than 6, EDSS scores). Hence it was not possible to estimate the size of the potentially protective effect across studies and the quality of the evidence base is currently insufficient for concrete effect estimates.

#### Sunscreen Use

Sunscreen use has been addressed in 2 studies.^36,60^ Both reported no association with MS progression but both used different outcome measures (reaching EDSS 6, MSSS scores), precluding concrete evidence statements.

#### Month of Birth

Three studies assessed whether the month of birth was associated with disease progression, often hypothesizing this affects the amount of sunshine a newborn is exposed to.^39 51,58^ One study reported on the time from onset to secondary progression, one on progression to EDSS 6, and one on MSSS scores. All reported no impact on disease progression but studies did not report on the same outcome measure and did not report numerical results other than the statistical significance of the association that would allow further analyses. The quality of the evidence base was determined to be insufficient for specific evidence statements.

#### Smoking

A large number of studies reported on smoking but studies used a variety of operationalizations of the risk factor and a range of different outcome measures. The forest plot summarizes the studies that reported on disease progression, either operationalized as time to reach EDSS 6, time to conversion to secondary progression, or time to progressive disease. The studies compared current and/or ever smokers with nonsmokers and/or never smokers. Data are primarily based on retrospective data collections.

Figure 3 Time to Progression and Smoking

Across studies we identified an increased risk of faster progression in smokers than nonsmokers (HR 1.55; CI 1.10, 2.19; I^2^ 72%; 7 studies, 8 datasets). However, there was evidence of substantial heterogeneity (that is, unexplained variation in results across studies). A subgroup analysis restricting to studies predicting time to secondary progressive MS (rather than progression to EDSS 6 or progression in all samples) showed a larger effect estimate, but the pooled effect was not statistically significant in this subset and substantial heterogeneity remained (HR 1.90; CI 0.73, 4.94; I^2^ 77%; 4 RCTs). There was also evidence of publication bias (rank test p = 0.179, regression test p = 0.038). A sensitivity analysis computing the trim-and-fill method to account for potentially missing studies estimated a smaller effect (HR 1.33, CIs 1.05, 1.85; 2 estimated missing studies), but nonetheless a still statistically significant effect.

The forest plot includes one out of 4 identified prospective studies.^97^ The other prospective studies could not be added to the meta-analysis because they reported on different measures. These studies reported conflicting results: one found no association between smoking status at baseline and EDSS scores over a period of 5 years (incidence rate ratio [IRR] 0.09; -0.17, 0.36)^69^ while another one found baseline smoking status to be a predictor of physical disability after 6 years.^112^ The third reported that the cumulative cigarette pack-years smoked after cohort entry was associated with an increase in longitudinal MSSS scores (p < 0.001).^76^

The body of evidence regarding an effect of smoking on the risk of progression was downgraded to moderate evidence quality due to unexplained heterogeneity in effect estimates across studies (inconsistency).

#### Diet

Evidence on dietary regimen was sparse and lacked detail.^21,36,38,54,60,63,98^ We did not identify more than one study reporting on the same diet or diet variable except fish consumption (see below). Studies addressing fat consumption did not report on the same outcome measure. Results across individual studies varied, with some studies showing associations with MS progression, others not; and results also varied within studies (comparing relapsing and progressive onset MS).^36^

The only identified prospective study reported on the Swank diet for MS patients and showed that for poor dieters, operationalized as participants with an intake of more than 20g fat per day, the average worsening significantly exceeded those of the good dieters, but the size of the effect was not reported.^98^ The quality of the evidence base was judged to be insufficient overall.

#### Fish Consumption

Fish consumption specifically, which is associated with vitamin D as well as fatty acid intake, has been evaluated in 3 studies: the Flemish registry survey, a study in patients with progressive MS registered in the VHA Multiple Sclerosis Surveillance Registry, and an Italian cohort.^36,60,63^ The studies differed in risk factor timing (current; in the last 2 years; intake as a child) and used different outcome measures. The existing retrospective studies reported conflicting results with regard to the presence or absence of a negative association with MS progression. The quality of evidence was determined to be insufficient for specific evidence statements.

#### Alcohol

Alcohol consumption or alcohol misuse has been addressed in 5 studies in total.^27,36,38,43,106^ Possible alcohol-related problems,^27^ moderate duration of alcohol use after MS onset (15 years or less as compared to those who did not consume alcohol or consumed it for more than 15 years),^38^ higher levels of alcohol consumption (using a 5-point scale ranging from never to daily)^43^ have been associated with lower EDSS score categories, that is less disability in participants consuming alcohol, in 3 identified studies. One study found an association of alcohol consumption (compared to no consumption) with a reduced risk to reach EDSS 6 in relapsing MS patients but not in patients with progressive onset MS.^36^ One study found that engaging in moderate alcohol consumption (up to 30g/day for women, up to 45g/day for men) compared to low or no alcohol consumption was associated with reduced odds of increased disability based on the PDDS (OR 0.59, p < 0.001).

No prospective study exists, and the identified studies reported predominantly on concurrent associations (measuring current intake and current disability status). We did not identify more than one study reporting on the same operationalization of alcohol consumption and the same progression or disability measure; hence, the quality of evidence was insufficient for effect estimates across studies.

#### Exercise

Although a handful of studies on physical exercise is available, we did not identify more than one study reporting on the same specific exercise variable and the same measure of MS progression.^36,43,62,64,68,87,96,123^ All identified studies reported an association between exercise and EDSS score or another measure of progression or disability, but the direction of effects varied by study design.

Only 2 identified studies were prospectively analyzed, predicting later progression from baseline physical activity.^68,96^ Both highlighted the possible role of premorbid or baseline physical activity on future progression. Neither reported on the primary outcome of the review. One reported that premorbid physical activity statistically significantly predicted the linear change in PDDS scores in patients with relapsing-remitting MS and emphasized the possible role of physical activity for lessening disability progression.^68^ The other reported that baseline exercise scores were negatively correlated with the annual change rate in functional limitations assessed with a self-reported incapacity status scale and discussed the potential positive impact of exercise on MS progression.^96^ The overall quality of evidence was determined to be insufficient for concrete evidence statements, given the differences in outcome and predictor measures.

#### Trauma

Two studies addressed exposure to brain trauma.^55,89^ Both reported that it is not a risk factor for MS progression, but studies used different outcome measures (mean increase in DSS per year, benign MS defined as DSS equal or lower than 2 after 11 or more years of MS duration). No concrete evidence statement could be formulated for an individual outcome that has been shown in more than one study.

#### Epidural Analgesia

The association with MS progression and epidural analgesia has been addressed in 3 studies, including 2 prospective and one retrospective study.^30,57,72^ None reported a statistically significant association with EDSS or DSS scores. We did not identify studies that reported on the change to secondary progression.

The quality of the evidence for the statement that epidural analgesia does not affect progression was downgraded due to phase of investigation and imprecision. The risk factor was identified in exploratory, not confirmatory, studies and the point estimate of the association was not reported in either study. Hence, the strength of association is not known (studies only reported the statistically significance of the association).

#### Oral Contraception

Three studies reported on oral contraceptive use with conflicting results within and across studies.^36,40,57^ The Flemish registry survey reported that use of oral contraceptives was related to an increased risk of reaching EDSS 6 in progressive but not in relapsing onset MS.^36^ A second study reported that patients who had used combined oral contraceptives continuously for at least one year had lower EDSS scores compared to never users, indicating a protective effect.^40^ A third study reported that women who started oral contraceptives after disease onset had lower EDSS scores than both never users and past users. A benign disease course was predicted by current oral contraceptive use compared to never or past users.^85^ Given that none of the studies compared an identical combination of risk factor and outcome measure operationalization, the quality of evidence was determined insufficient for concrete evidence statements.

#### Geographic Region

Two studies addressed geographic regions but in different operationalizations (eg, high vs low MS prevalence areas; geographic region of military personnel at entry to the military) and studies used different outcome measures (3-point scale differentiating walking without aids, walking with aids, and restricted to wheelchair; progression to DSS 6 and DSS7).^35,105^ Only one of the studies reported an association; progression to a non-ambulatory status or death was significantly greater among patients who lived in Los Angeles County (a low-prevalence area). The different outcome measures, risk factor operationalizations, and conflicting results cannot be combined to a concrete evidence statement.

#### Education

Two studies investigated an association between education and MS progression.^22,99^ Both studies were retrospective analyses, they reported on EDSS greater than 6 or MSSS scores, and they reported conflicting results. One study assessing MSSS did not find that education predicted getting statistically significantly worse in a sample of 338 patients, the other one reported that lower educational attainment predicted EDSS scores above 6 (OR 1.5; CI 1.2, 2.8). Given the lack of replication on outcome measures and the conflicting results, the quality of evidence was rated insufficient.

#### Other Factors

All other factors have been addressed in only one of the included studies and have not been replicated yet. The study details together with the results are shown in the evidence tables.

#### KQ1 Summary

The summary of findings table documents the available evidence for specific risk factors and specific outcome measures that were reported in more than one study. We did not include results that were based on a single study without replication by another, independent author group, given the complexity of epidemiological data collection.

Results (strength and statistical significance of the association) for EDSS scores and for other MS progression-relevant findings were summarized across studies. For each outcome, the GRADE summary is documented. The summary of findings tables is organized by outcome and where outcomes were not identical or not compatible across studies, no effect estimate could be determined and the evidence was consequently graded as insufficient for concrete evidence statements. The table shows the presence and the absence of associations, and factors delaying as well as hastening progression have been considered.

Table 8 Summary of Findings for KQ1

Risk factor and Outcome measure | Study Design, # of Studies | EDSS Findings: Direction, Magnitude of Effect | Other Progression Findings: Direction, Magnitude of Effect | GRADE
Vitamin D
Correlation 25(OH)D level and EDSS | 8 concurrent, 1 retrospective, 1 prospective study | Weak correlation (r -0.22; CI -0.28, -0.10) indicating lower levels of vitamin D are associated with higher EDSS scores | | Moderate (indirect)^*^
Sun Exposure
No outcome assessed in > 1 study | 5 retrospective studies | N/A (see text) | N/A | Insufficient
Sunscreen Use
No outcome assessed in > 1 study | 2 retrospective studies | N/A (see text) | N/A | Insufficient
Month of Birth
No outcome assessed in > 1 study | 3 retrospective studies | N/A (see text) | N/A | Insufficient
Smoking
Risk of progression comparing smokers and nonsmokers | 6 retrospective, 1 prospective study | N/A | Smoking is associated with an increased risk of progression (HR 1.55; CI 1.10, 2.19) | Moderate (heterogeneity)^*^
Diet
No outcome assessed in > 1 study | 2 concurrent, 4 retrospective, 1 prospective study | N/A (see text) | N/A | Insufficient
Fish Consumption
No outcome assessed in > 1 study | 3 retrospective studies | N/A (see text) | N/A | Insufficient
Alcohol-related Variables
No outcome assessed in > 1 study reporting on the same operationalization | 3 concurrent, 2 retrospective studies | N/A (see text) | N/A | Insufficient
Exercise
No outcome assessed in > 1 study | 2 retrospective, 3 prospective studies | N/A (see text) | N/A | Insufficient
Trauma
No outcome assessed in > 1 study | 2 retrospective studies | N/A (see text) | N/A | Insufficient
Epidural Analgesia
EDSS scores | 2 prospective studies, 1 retrospective study | 2 studies showed no association with EDSS scores (sign. N/A) or 3 EDSS score categories (p > 0.1) | One study showed no statistically significant association with EDSS or DSS (p = 0.66) | Low (exploratory, no point estimate)^**^
Oral Contraception
No outcome assessed in > 1 study | 3 retrospective studies | N/A (see text) | N/A | Insufficient
Geographic Region
No outcome assessed in > 1 study | 1 retrospective, 1 prospective study | N/A (see text) | N/A | Insufficient
Education
No outcome assessed in > 1 study | 2 retrospective studies | N/A (see text) | N/A | Insufficient

Note: The table only shows risk factors that were reported in more than one study;

* quality of evidence downgraded by 1 level,

** quality of evidence downgraded by 2 levels

## KEY QUESTION 2 What environmental exposures prior to or during military service are related to multiple sclerosis progression following onset symptoms?

Despite the extensive search, very few relevant studies were identified. In addition, only some of the studies addressed environmental exposures during military service. The remaining studies addressed other factors in samples of Veterans.

One of the studies has been presented in the context of diet risk factors (evidence table 4). The study evaluated MS in men on active duty in the US Army. It reported on the disease course for patients that were put on a specific diet in the hospital, compared to patients without administration of a specific therapy.^54^ The reported data were not statistically significantly different between groups. However, no information was available on the specific diet and approaches may have varied across patients and hospitals.

A second study focused on disability and treatment patterns of MS patients in Veterans and non-veterans. The concurrent study reported that VHA Veterans had statistically significantly higher PDDS scores than non-veterans.^104^ More information is presented in table 6, the evidence table summarizing “other” MS progression risk factors.

Two additional studies reported on multiple risk factors of interest and are shown in more detail in evidence table 7. One study reported on a Gulf War-era MS cohort which includes 2,631 patients.^105^ The study reported that deployment to a war theater, geographic location, and occupational status at entry to the military were not predictors of progression to DSS 6 and DSS 7. The study was reported in a conference abstract and data on the exact point estimate and measure of dispersion were not available.

The fourth study addressed vitamin D exposure and reported on the average fall/winter sun exposure before MS onset, cod liver oil intake as a child (ages 6 to 15), and fish consumption between the age of 6 and 15.^63^ The study reported on 219 Veterans with progressive MS registered in the Multiple Sclerosis Surveillance Registry. The study used the PDDS to assess progression and predicted hazard ratios for the time to reach a PDDS score of 8 from disease symptom onset. This stage indicates that a wheelchair or scooter is the main form of mobility. The study reported low average sun exposure in the fall/winter before disease onset was associated with an increased risk of progression (HR 2.13; CI 1.20, 3.78) and cod liver oil during childhood and adolescence was associated with a reduced risk (HR 0.44; CI 0.20, 0.96). Fish consumption was not statistically significantly associated with PDDS progression in this sample. The study concluded that exposure to vitamin D before MS onset may slow disease-related neurodegeneration and thus delay progression to disability in patients with progressive MS.

### Summary of Findings and Quality of Evidence for Key Question 2

The summary of findings table showing KQ2 evidence is grouped by exposures prior to or post military service and exposures during military service. All studies relevant to KQ2 also contribute to KQ1 and were already included in KQ1 evidence statements.

Table 9 Summary of Findings for KQ2

Risk Factor | Study Design, # of Studies | EDSS Findings: Direction, Magnitude of Effect | Other Progression Findings: Direction, Magnitude of Effect | GRADE
Prior or Post Military Service in Veterans
Geographic location at entry to the military | 1 retrospective study, N = 2631 | N/A | Geographic location was not a predictor of progression to DSS 6 and DSS 7 (magnitude of effect N/A) | Insufficient
Occupational status at entry to the military | 1 retrospective study, N = 2631 | N/A | Status was not a predictor of progression to DSS 6 and DSS 7 (magnitude of effect N/A) | Insufficient
Average fall/winter sun exposure before MS onset | 1 retrospective study, N = 219 | N/A | Low sun exposure was associated with faster progression (HR 2.13; CI 1.20, 3.13) | Insufficient
Cod liver oil intake at ages 6-15 | 1 retrospective study, N = 219 | N/A | Cod liver oil intake was associated with slower progression (HR 0.44; CI 0.20, 0.96) | Insufficient
Fish consumption at ages 6-15 | 1 retrospective study, N = 219 | N/A | No statistically significant association with progression (HR 0.79; CI 0.45, 1.41) | Insufficient
Exposure During Military Service
Deployment to a war theater | 1 retrospective study, N = 2631 | N/A | Deployment to a war theater was not a predictor of progression to DSS 6 and DSS 7 (magnitude of effect N/A) | Insufficient
Being a Veteran | 1 concurrent study; N = 2150 | N/A | VHA Veterans had higher PDDS scores than non-veterans (p < 0.001) | Insufficient
Diet in hospital | 1 retrospective study, N = 517 | N/A | Diet group: 28% better, 56% the same, 16% worse; patients with hospital routine without specific treatments: 19% better, 74% same, 8% worse (p = 0.131) | Insufficient

Note: N/A not reported, not available

None of the identified studies were prospective studies, which allow more confident interpretations of associations. In addition, all associations were based on only one study, and without any replication in independent studies, the available evidence was graded as insufficient. Some of the factors shown in this summary of findings table were uniquely addressed in the KQ2-relevant studies, such as deployment. Other investigated factors, such as sun exposure, have been addressed in other studies documented in the KQ1 evidence synthesis; however, the exact operationalization of the factors, for example sun exposure during childhood and teenage years, also has not been replicated in other available studies by independent author groups.

## KEY QUESTION 3 Among identified risk factors for progression, what treatment/risk factor modification therapies have been shown to delay or hasten the progression of MS once it has initiated?

We identified a substantial number of intervention evaluations; however, they addressed only a small range of interventions. Despite the comprehensive search and inclusive inclusion criteria, all identified studies evaluated either vitamin D supplementation, exercise interventions, or dietary interventions.

Details of included studies contributing to KQ3 are presented in 3 evidence tables in the following text.

The largest group of interventions addressed physical exercise.

Table 10 Evidence for KQ3: Effects of Exercise Interventions on MS Progression

ID, Trial type^§^ | N Power | Participants | Intervention | Co | Comparator | EDSS results | Other results | AE
Armutlu, 2001^19^ | 26 No power calculation | Patients with ataxic MS, intervention group mean age 32.61 (23-44), 9 female, 4 male, EDSS 4.53 (3.5-5.5); control group mean age 34.61, (range 26-45), 7 female, 6 male; PP and SP; Poser criteria | Neuromuscular rehabilitation with pressure splints, 3× / week for 4 weeks | | Neuromuscular rehabilitation alone | Significant improvements in EDSS scores in both groups, no difference between groups (p > 0.05) | | N/A
Bjarnadottir, 2007^26^ | 16 (6 treatment, 10 control) No power calculation | Patients with mild MS aged 18-50 years with definite MS and EDSS < 4, and with the ability to ride a stationary bicycle; mean age 38.7 vs 36.1, mean EDSS 2.1 vs 1.8, mean duration of MS 8.7 vs 8.3 years; Poser criteria | Training 3× / week for 5 weeks or a total of 15 hours; aerobic exercise, resistance exercise and stretching and relaxation | | No treatment | No change in EDSS was detected and groups did not differ in pre-post difference (-0.07, CI -0.7, 0.61) | | 1 patient in each group developed a relapse and was withdrawn, transient increase in symptoms was not observed
Carter, 2013^125^ | 28 No power calculation | Patients with MS, mean age 40 years (24-49) with mild to moderate EDSS = < 5.5; treatment vs usual care: female 87.5% vs 85.7%, mean age 39.5 (SD 6.5) vs 40.9 (SD 8.7), mean EDSS 3.0 (SD 1.1) vs 3.1 (SD 1.7); McDonald 2010 criteria | 10 week pragmatic exercise intervention (2 supervised and 1 home-based session / week) | | TAU | Lower EDSS scores in intervention group after 10 weeks (p = 0.07) and 3 months post-intervention (p = 0.48) compared to control | | N/A
Conklyn, 2010^31^ | 10 No power calculation | Adult MS patients with gait disturbance, able to walk 100 feet without physical assistance; treatment vs control: mean age 47 (SD 10.51) vs 50.2 (SD 5.45), 60% vs 80% female, relapsing-remitting 80% vs 60%, SP 0% vs 40%, primary progressive 20% vs 0%; criteria N/A | 2 week Rhythmic Auditory Stimulation | | No treatment | | No statistically significant changes in PDDS scores | N/A
Dalgas, 2009^32^ cross-over | 38 Power unclear | Moderately impaired patients with MS, treatment vs control: female 10/16 vs 10/15, mean age 49.1 vs 47.7, mean EDSS 3.9 vs 3.7, mean time since diagnosis 8.1 vs 6.6; McDonald 2001 criteria | Biweekly 12-week lower extremity progressive resistance training program, participants encouraged to continue training afterwards | | No treatment | EDSS remained unchanged in both groups | | N/A
DeBolt, 2004^34^ | 36 (19 treatment, 17 control) No power calculation | Healthy adults with MS and the ability to walk (with or without assistive devices) at least 20m without rest, EDSS scores ranged from 2 to 6, 29 women (mean age, 50.3, SD 8.5) and 8 men (mean age 51.1, SD 7.1); criteria N/A | Home-based resistance exercise (8-week) | | No treatment | No significant differences between groups after intervention (p = 0..552) | | N/A
Fimland, 2010^37^ | 14 No power calculation | Maximal strength training vs control group: female 75% vs 75%, mean age 53 vs 54, mean EDSS 4.6 vs 3.5, years since diagnosed 8 vs 8; criteria N/A | A rehabilitation program, maximal strength training using high loads and few repetitions, 5 days/wk for 3 wks | | No treatment | No changes were observed for the EDSS between groups.,scores remained unchanged in all participants | | No adverse effects
Golzari, 2010^42^ | 20 No power calculation | Women from MS society and clinic, age 20-50, with clinically diagnosed R-R and EDSS 0-4; exercise vs control: mean age 32.5 (SD 7.57) vs 33.75 (SD 8.18), mean EDSS 2.14 (SD 1.06) vs 1.96 (SD 1.06); criteria N/A | Combined exercises for 24 sessions during 8 wks; 1-hour session with warm-up, stretch, aerobic, endurance, and resistance training, and relaxation | | No treatment | Score was decreased in intervention group 8 weeks after training (p < 0.43) but not control group | | N/A
Lo, 2008^56^ cross-over | 13 No power calculation | R-R, SP, and PP MS patients, mean age 49.8 (SD 11.1), EDSS 4.9 (SD 1.2), female 6/13, R-R 8/13, PP 5/13; McDonald 2001 criteria | Body weight supported treadmill training with or without robotic assistance training sessions, 2/week for 3 weeks, a total of 6 sessions of 40 mins | | Reversed treatment order | Significant improvement in EDSS scores in both groups: -0.83 (SD 0.61, p = 0.06) and -1.1 (SD 0.7, p = 0.03) | | No adverse events occurred
Miller, 2011^66^ | 30 Insufficient power | Patients with PP or SP MS and EDSS scores 6.5-8; intervention vs control: 26.7% vs 46.7% female, mean age 56.3 vs 52.9, time since diagnosis 13 vs 18.7, EDSS 7 vs 7.1; definitive diagnosis, criteria N/A | 8 week physiotherapy | | TAU | EDSS: no interaction effect over time (p = 0.803) or group effect (p = 0.074) | | None
Petajan, 1996^126^ | 46 No power calculation | Ambulatory MS patients recruited through MS society and physician referrals, exercise vs non-exercise: female 71.4% vs 76%, mean age 41.4 (SD 2) vs 39 (SD 1.7), EDSS 3.8 (SD 0.3) vs 2.9 (SD 0.3), years since first symptoms 11.6 (SD 1.7) vs 10.5 (SD 1.6), years since diagnosis 9.3 (SD 1.6) vs 6.2 (SD 1.1); Poser criteria | 15 weeks aerobic training with 3 supervised training sessions per week (5 minute warm-up, 30 mins at 60% maximum aerobic capacity, 5 min cooldown) | | No treatment | Overall EDSS scores did not change (-0.1 in exercise group, -0.1 in nonexercise group) | | N/A
Pfalzer, 2011^75^ | 39 No power calculation | Ambulatory patients with clinically diagnosed MS; 22 with R-R, 5 SP, 5 PP, 3 PR, 4 unknown; clinically diagnosed, criteria N/A | Home-based exercise training (10 weeks) | | No treatment | Intervention: EDSS mean 4.3 (SD 1.9, improvement pretest-posttest 0.2 (0.7)), Control: 3.7 (SD 1.6); pre-post 0.5 (SD 1.2) post-intervention | | 2 dropped out due to medical illness unrelated to MS
Rampello, 2007^79^ cross-over | 19 No power calculation | Patients aged 20-55 years with MS on waiting list for rehabilitation program with EDSS < 7; treatment vs control: mean age 44 vs37, female 8/11 vs 6/8, mean disease duration 6 vs 10 years, mean EDSS 3.5 vs 3.25; Poser criteria | Aerobic training (8 weeks) | | Other: neurological rehabilitation | No change over time was found in EDSS (p = 1.0) | | 2 dropped out due to perception of breathlessness and fatigue
Romberg, 2004^81^ cross-over | 114 Sufficient power | Patients aged 30-55 with definite MS and EDSS -5.5; exercise vs control: female 30/47 vs 41/48, mean age 43.8 vs 43.9, mean years after 1st symptoms 9.7 vs 9.6, mean years after diagnosis 6.0 vs 5.5, mean EDSS 2.0 vs 2.5; Poser criteria | Strength and aerobic training initiated during 3-week inpatient rehabilitation and continued for 23 weeks at home | | TAU | No change (p = 0.93) over time in EDSS | | No exercise-related injuries; 5 relapses in intervention group and 6 in control group in 9 patients
Sangelaji, 2014^83^ | 147 Power unclear | MS patients, EDSS score 0-4; criteria N/A | Aerobic, strengthening, balancing, and stretching exercises (10 weeks) | | No treatment | No significant changes in EDSS at any follow-up, but both control and intervention increased EDSS scores at 1-year follow-up (intervention: 0.5 points, p = 0.001; control: 0.72 points, p = 0.001) | | 1 dropped out due to muscular pain in cuff muscles, 1 due to new attack and nonresponding symptoms
Schwartz, 2012^84^ | 32 Insufficient power | MS patients with chronic progressive pattern or relapsing-progressive with no relapse for 3 months (RP, SP, and PP); robot-assisted vs conventional: female 41% vs 43%, mean age 50.5 (SD 11.5) vs 46.8 (SD 11.5), disease duration 14.9 (SD 8.1) vs 11.3 (SD 6.7), EDSS 6 (SD 0.6) vs 6.2 (SD 0.5); McDonald 2001 criteria | 12 sessions of robot-assisted gait training (gait orthosis) or conventional walking treatment 2-3 times a week (30 min net treatment) for 4 weeks | | Conventional walking treatment | EDSS scores improved significantly post-treatment with no difference between the groups; mean changes in EDSS robot-assisted vs conventional post-intervention: -0.29 (SD 0.4) vs -0.31 (SD 0.3); at 3 months -0.22 (SD 0.4) vs -0.27 (SD 0.3); at 6 months -0.21 (SD 0.4) vs -0.25 (SD 0.4) | | N/A
Solari, 1999^92^ | 50 Sufficient power | MS patients aged 18-65, EDSS 3-6.5, mean EDSS 5.5; treatment vs control: 63 vs 48% female, mean age 44.6 (SD 10.2) vs 44.9 (SD 10.9), R-R 22.2 vs 21.7%, PP 14.8 vs 17.4%, SP 63 vs 60.9%; clinically definite or laboratory-supported MS | 3 week inpatient physical therapy | | Exercise at home | No changes in impairment occurred in either group (EDSS scores) | | N/A
Wiles, 2011^109^ cross-over | 42 Power unclear | MS patients with walking difficulties, able to walk 5 meters without any physical assistance, mean age 47.2 (28.2-68.8), 35.7% female, mean duration of disease onset 4.4 (SD4.6); Poser criteria | Allocation to one of 6 permutations of three 8-week treatment periods separated by 8-week intervals: physiotherapy at home or no therapy | | No treatment | | Effects favored hospital- or home-based therapy over no therapy | N/A

Notes: AE adverse events, Co co-intervention, N/A not available, TAU treatment as usual, R-R relapsing-remitting, PP primary progressive, SP secondary progressive, vs versus

§ All studies are RCTs unless otherwise noted.

The 18 studies tested a range of physical interventions, including aerobic exercise, resistance training, physiotherapy, or rehabilitation with maximal strength training. Settings were home-based or rehabilitation centers. The majority of studies compared the program to no treatment; 3 studies compared to treatment as usual.^29,66,81^ Two studies assessed the comparative effectiveness of a robot-assisted intervention^84,56^ and one the effect of adding pressure splints to the training.^19^ The training duration ranged from 2 to 26 weeks.

Studies enrolled between 10 and 147 participants. The majority of included studies was small and did not report a statistical power calculation. Four studies reported a power calculation but for a different outcome than MS progression or disability scores.^32,81,83,109^ Two studies reported that power was insufficient even for the primary outcome.^66,84^ Only one study took EDSS scores into account for the power calculation; the study reported no changes in impairment occurred in either group after 3-week inpatient physical therapy or exercise training at home.^92^

The identified studies were primarily in patients with mild MS who were ambulatory. However, 2 of the included studies were specifically designed to test the comparative effectiveness of robot-assisted gait training compared to conventional walking treatment or adding pressure splints to the training in patients with progressive MS; EDSS scores improved in both intervention arms.^19,84^

All included studies reported on disability of MS measured by the primary outcome of this review – EDSS scores. However, in none of the studies was MS progression a primary outcome, and only selected studies reported EDSS assessments to be a secondary outcome^42,74,75,83,84^ to evaluate the intervention. Given the short duration of the intervention, many studies reported no substantial changes in EDSS levels after the intervention.

Half the studies did not report on adverse events. Reported adverse events were relapses,^26,81,83^ breathlessness and fatigue,^79^ muscular pain,^83^ and unrelated illnesses.^75^ Two studies assessed adverse events and reported that none occurred.^37,56^

The risk of bias assessment for the identified studies is shown in Appendix C. Performance bias was a prominent source of bias in the identified interventions because blinding of participants and personnel was not possible given the nature of the intervention. In addition, only selected studies ensured that the outcome assessors were blind to the treatment condition. Two studies, Fimland et al and Petajan et al, had noticeable imbalanced samples at baseline, with intervention patients that had higher EDSS scores than the control group.^37,127^ While the internal validity of included studies varied, several studies were not particularly suitable to assess the outcome of interest due to the short duration of the intervention. Only 11 out of 18 studies reported on an intervention with a duration of 2 months or more.^29,32,34,42,66,74,75,79,81,83,109^

The second group of intervention studies reported on dietary interventions. The details of included RCTs are shown in the following evidence table.

Table 11 Evidence for KQ3: Effects of Dietary Interventions on MS Progression

ID, Trial type^§^ | N Power | Participants | Intervention | Co | Comparator | EDSS results | Other results | AE
Bates, 1977^24^ | 152 No power calculation | Patients with chronic progressive non-relapsing MS; criteria N/A | Group A: 8 capsules of 360mg linolenic and 3-42 g of linoleic acid daily; group B: placebo capsules (oleic acid oil); group C received 11.5 g/day of linoleic acid spread; group D placebo spread (oleic acid) for [presumably] 24 months | | Placebo | | No statistically significant difference between groups in the number of patients who improved, deteriorated, or remained unchanged | N/A
Bates, 1978^25^ cross-over | 116 (29 for each of 4 groups) No power calculation | Patients with remitting MS; Group A vs B, C vs D: female 19/29 vs 19/29, 24/29 vs 18/29; mean age 35 vs 32, 34 vs 33; mean duration of disease 7 vs 6, 7 vs 6; criteria N/A | Group A: 8 capsules daily (2 92g linoleic acid, 0 34g gamma-linolenic acid); Group B: 8 similar capsules (4 g oleic acid, control); Group C: 23g linoleic acid daily in a spread; Group D: 16g oleic acid in a spread (control) for [presumably] 24 months | | Placebo | | After 2 years, the number of patients who had deteriorated (DSS and additional assessment) in intervention group A was significantly greater than that in the control group B (p < 0.05) | N/A
Bates, 1989^23^ multi-center | 312 No power calculation | Patients aged 16-45 years with definite MS, suffered at least 2 relapses with 1 during last 24 months, EDSS =< 6.0, treatment vs control: female 102/155 vs 109/157, mean age 34 vs 33, mean duration of disease 6.5 vs 6.6; McDonald & Halliday criteria | 20 capsules of 0.5 g of omega-3 fatty acid (1.71 g C20:5 and 1.14 g C22:6 per day) for [presumably] 24 months | | Placebo | Intervention: 51% better, 43% worse, 1 patient died; placebo (olive oil): 41% better, 52% worse, no deaths (difference p = 0.07) | | 1 patient died
Harbige, 2007^44^ | 36 No power calculation | Patients with active MS; international MS criteria | High or low dose of gamma-liolenic acid (18:3n-6)-rich borage oil (high in sn-2 GLA, low in monoenes, natural levels of vitamin E) for 18 months | | Placebo | High-dose treatment significantly reduced disability progression (EDSS) compared with placebo and low dose treatment (no numerical results) | | N/A
Millar, 1973^65^ | 87 (36 treatment, 39 control) No power calculation | MS patients, treatment vs control: mean age 37.8 vs 35.5, female 56% vs 64%, average age at onset 38 vs 36, mean duration of symptoms before entry 7.7 vs 9.2, mean disability score 2.9 vs 2.7; criteria N/A | Linoleate supplementation (30 ml sunflower seed oil, 8-6g of linoleic acid, 2/day) for 2 years | | Placebo | | Placebo (olive oil) deteriorated from 2.7 to 3.3 at the end of the trial, treatment group from 2.9 to 3.1 (n.s.) | N/A
Pantzaris, 2013^71^ | 80 (20 each in 4 groups) No power calculation | R-R patients aged 18-65 years, EDSS 0-5, with at least 1 documented clinical relapse; McDonald criteria | Intervention A: omega-3 and omega-6 polyunsaturated fatty acids at 1:1 wt/wt; Intervention B: combination of A and gamma-tocopherol; intervention C: gamma-tocopherol; Control: placebo (olive oil).; 19.5 ml / day for 30 months | | Placebo | The cumulative probability of progression of EDSS with 1 point increase at 2 years was 10% in the combination group and 35% in the placebo group (p = 0.052), adjusted HR 0.22 (CI 0.04, 1.07; p = 0.06)) | | No significant AE, nausea N = 2, no abnormal values in biochemical and blood tests, no allergic reactions
Paty, 1978^73^ | 96 No power calculation | Patients with definite MS, ambulatory (either on their own or with ambulatory aids); treatment vs control: mean age 45 for both, mean age onset 32 vs 30, duration of disease 13 vs 16, mean DSS 4.24 vs 4.26; Schumacher criteria | Linoleic acid (1 oz, 2/day, sun flower seed oil, 66.2% linoleic acid) for 30 months | | Placebo | | Final disability scale score for intervention vs placebo (olive oil): 3.52 vs 3.85, changes from baseline: -0.72 vs -0.41 (n.s.) | N/A
Ramirez-Ramirez, 2013^78^ | 50 Power unclear | Patients with R-R, at least 1 relapse in year before, EDSS score 0-5, treated with interferon beta-1b; intervention vs placebo: female 17% vs 18%, mean age 35 (SD 7.6) vs 35 (SD 7.8), mean EDSS 2.1 (SD 0.98) vs 2.06 (SD 0.84), years with disease 7.1 (SD 4.8) vs 6.7 (SD 6.7); McDonald 2005 criteria | Fish oil (4 g/day, 0.8g EPA, 1.6g DHA, and excipient) for 12 months | Interferon beta-1b | Placebo | EDSS changes from baseline to 12 months: 0.1 in intervention, 0.2 in placebo group (group differences n.s.) | | No serious adverse effects; no changes in liver and renal tests, platelets, blood count, bleeding; fishy taste; < 5% reported nausea, stomach pain, diarrhea
Rezapour-Firouzi, 2013^80^ | 100 No power calculation | R-R; group A vs B vs C: mean age 34.2 (SD 7.5) vs 35.9 (SD 7.8) vs 33.7 (SD 7.8); average age at onset 25 (SD 7.5) vs 30.3 (SD 8.1) vs 27.6 (SD 6.4); disease duration 6.23 (SD 3.9) vs 7.55 (SD 5.08) vs 6.6 (SD 4.0); female 69.6% vs 50% vs 75%; baseline EDSS 2.76 (SD 1.39) vs 3.45 (SD 1.41) vs 3.25 (SD 1.9); criteria N/A | Group A: hemp seed and evening primrose oils with Hot nature diet (foods with Hot nature; low intake of cholesterol, hydrogenated / trans fatty acids and saturated fats (fried food), olive / grape seed oil, fresh fruit and vegetables, nuts and seeds, fish and seafood, unrefined carbohydrates, plenty of water, cutting down sugar and refined starch, dairy products with honey or date, removing foods with Cold nature); Group B: hemp seed and evening primrose oils for 6 months | | Placebo | Significant improvements in EDSS in intervention groups, significant increase in EDSS score in control group (olive oil) | | No serious adverse effects in any of the patients
Torkildsen, 2012^101^ multi-center | 92 Power unclear | R-R patients, 18-55 years, EDSS = > 5.0; fatty acids vs placebo: female 30/46 vs 29/45, mean age 28.8 vs 28.3, mean EDSS at baseline, 1.94 vs 1.86, mean disease duration 5.4 vs 5.8 years, mean relapses the year prior 1.7 vs 1.6, mean time since diagnosis 2.2 vs 1.7; McDonald 2001 criteria | Oral omega-3 fatty acids (270mg EPA, 170mg DHA) and 4 units of alpha-tocopherol per gram for 18 months | Interferon beta-1a | Placebo | After 24 months, EDSS increased to 2.22 (1.34) in the fatty acids group and 2.19 (1.34) in placebo group (p = 0.63); 30% in the fatty acids group vs 30% in the placebo group had experienced disease progression (p > 0.99) | No differences in changes of MS Functional Composite scores after 6 (p = 0.53) or 24 (p = 0.57) months | 74% intervention, 63% placebo experienced AE (eg, influenza-like symptoms, injection site reaction), n.s. between groups; 1 intervention patient (nausea) and 2 placebo patients (allergic reaction) withdrew
Weinstock-Guttman, 2005^107^ cross-over | 31 No power calculation | MS patients, 18-60 years; intervention vs placebo: female 85.7% vs 84.6%, mean age 45.1 vs 39.9, mean disease duration 6.9 vs 4.6, mean EDSS 1.9 vs 2.0; Poser criteria | Very low-fat diet dietary advice (not to exceed 15% of total daily calories) plus fish oil supplement (6 capsules / day, 1.98g EPA, 1.32 DHA); control group received AHA diet advice (30% fat) plus placebo | | Other | Weak trend towards an increase in EDSS (+0.35) in the control group vs a decrease of 0.07 points in the intervention group after 1 year | | 2 could not tolerate the diet (1 per group)
Yadav, 2014^110^ | 61 No power calculation | R-R (mean EDSS 2.5; mean age 41, range 24-55); criteria N/A | Low-fat plant-based diet (1 year) | | Waitlist | After baseline difference adjustment, the groups showed no siginificant change in EDSS | | “study demonstrated safety”

Notes: AE adverse events; Co co-intervention, N/A not available, n.s. not statistically significant, R-R relapsing-remitting, PP primary progressive, SP secondary progressive, vs versus

§ All studies are RTCs unless otherwise noted.

The majority of the 12 dietary intervention studies addressed effects of fatty acid supplementation. Three studies evaluated the effects of advice for a diet of foods with “Hot nature” according to traditional Chinese medicine, a very low-fat diet plus fish oil, and a low-fat plant-based diet.^80,107,110^ Studies compared interventions primarily to placebo. One study compared to patients assigned to waitlist (patients will receive the intervention eventually).^110^ Another compared to different, not very low-fat diet advice plus placebo instead of fish oil supplementation.^107^ All studies tested long-term interventions; the duration ranged from 6 to 30 months.

Studies enrolled between 31 and 312 patients. Studies either reported no power calculation to determine the sample size necessary to detect a statistically significant difference between treatment groups, or it was computed for a different outcome than MS progression or disability scores. One of the included studies tested the intervention specifically in chronic progressive non-relapsing MS,^24^ while other studies used unrestricted MS samples or did not report on the form and stage.

Several studies reported on EDSS results but not all reported EDSS endpoint values to allow a comparison between intervention and control groups. Some studies only stated the statistical significance of the difference, reported the statistical significance of the difference between baseline and endpoint for each group, or reported no specific numbers. Four included studies were published before the development of the EDSS and reported on the number of patients who deteriorated.^24,25,65,73^ The adverse event assessment was sparse; 5 included studies did not report on adverse events at all, 3 reported adverse events but did not specify the treatment group patients were assigned to, and 2 gave no details on the experienced events. Only 2 studies reported on adverse events by intervention group and reported that one or 2 patients withdrew from the study.

The risk of bias assessment for the identified studies is shown in Appendix C. There was insufficient detail to assess the risk of bias in a number of dietary intervention studies, in particular the studies that were published 40 years ago, presumably due to differences in reporting standards.^24,25,65,73^ Compliance in diet advice studies was judged to be a source of other bias, given the long duration of the intervention that required the participants to adhere to a demanding dietary schedule.^80,107,110^

Studies reporting on vitamin D supplementation are shown in the following, final evidence table. Studies exclusively gave dietary supplements to patients, rather than addressing more complex nutritional changes or dietary habits.

Table 12 Evidence for KQ3: Effects of Vitamin D Supplementation Interventions on MS Progression

ID, Trial type^§^ | N Power | Participants | Intervention | Co | Comparator | EDSS results | AE
Burton, 2010^28^ multi-center | 49 Power unclear | MS clinic patients, mean age 40.5 years, EDSS 1.34, and 25(OH)D 78 nmol/L; treatment vs control: female 84% vs 70%, R-R/SP 23/2 vs 22/2, mean disease duration 8.2 vs 7.4; patients already taking > 4,000 IU/day were excluded; McDonald 2001 criteria | Escalating vitamin D doses up to 40,000 IU/day over 28 weeks followed by 10,000 IU/day, and further downtitrated to 0 IU/day; calcium 1,200 mg/day; for 52 weeks | | Placebo | Treatment vs control EDSS (p > 0.5), % change in EDSS -0.23 vs 0.30 (p > 0.5), proportion completing with increased EDSS 0.88 vs 0.375 (p = 0.019) at end of trial | No adverse events observed
Kampman, 2012^49^ | 68 (35 treatment, 33 placebo) No power calculation | Patients aged 18-50 with clinically definite MS and EDSS = < 4.5; vitamin D vs placebo: female 69% vs 73%, mean age 40 vs 41, mean duration from first symptom (range) 11 (1-27) vs 10 (2-26) years, mean EDSS 2.5 vs 2.0, mean MSSS 3.6 vs 3.2; McDonald 2001 criteria | 20,000 IU vitamin D3 once a week in capsule for 96 weeks | | Placebo | No significant difference in EDSS between treatment and placebo groups (absolute difference -0.01, CI -0.35, -0.35, p = 0.091) | 1 placebo patient dropped out due to nephrolithiasis
Mosayebi, 2011^67^ | 62 (28 treatment, 34 placebo) No power calculation | MS patients, 18-60 years, at least 1 relapse in the previous 12 months; > 3 lesions on spinal or brain-MRI or both; EDSS 0-3.5; vitamin D vs placebo: female 17/26 vs 25/33, mean age 37 vs 35, mean duration of disease 4.15 vs 6.4 years; patients with progressive MS were excluded; McDonald 2001 criteria | 300,000 IU vitamin D3 as intra-muscular injections every month for 6 months | | Placebo | EDSS increased by 0.21 from 2.10 after 6 month intervention and by 0.17 from 2.5 in placebo group | N/A
Shaygannejad, 2012^88^ | 50 Sufficient power | MRI, clinical, or laboratory-supported R-R, EDSS < 7, average age 38.6; PP and SP MS excluded; McDonald 2005 criteria | Low-dose vitamin D (calcitriol) for 1 year | DMT | Placebo | Intervention: EDSS 1.63 (SD 0.70, difference pre-post 0, CI -0.15, 0.15); Placebo: 1.94 (SD 1.41, difference pre-post -0.24, CI -0.40, -0.08; p < 0.01) at 12-month follow-up | Vitamin D was well-tolerated; most AE were mild. Most common in intervention vs placebo group: constipation (N = 6 vs 4), dyspepsia (N = 6 vs 2), fatigue (N = 4 vs 5), headache (N = 2 vs 1)
Soilu-Hanninen, 2012^128^ multi-center | 66 (34 treatment, 32 placebo) Power unclear | R-R patients age 18-55 years with IFNB-1b use for at least 1 month and EDSS = < 5.0; vitamin D vs placebo: female 21/34 vs 20/32, mean age 39 vs 35, mean EDSS 2.0 vs 2.4, mean disease duration 3.0 vs 2.4, mean annual relapse rate from the 2 years before the study onset 0.49 vs 0.52, patients with relapses during the year preceding baseline 12/34 vs 13/32; McDonald 2005 criteria | Vitamin D3 (20,000 IU or 0.5 mg of vitamin D3 in capsule, once weekly) for 1 year | | Placebo | EDSS score decreased in the vitamin D group by -0.2 from 1.8 and remained the same in the placebo group (-0.02) after the 12 months intervention (p = 0.071) | No hypercalcaemia or significant differences in any clinical chemistry parameters or AE between groups; diarrhea (intervention N = 5 vs control 2), fever (2 vs 5); SAE: 1 case of erysipelas treated with antibiotics in intervention, 2 hospitalizations in control group (elective hip surgery, elbow fracture)
Stein, 2011^94^ | 23 No power calculation | Patients with R-R older than 18 years, relapse within the preceding 24 months; intervention vs placebo, mean age 34 (29.5-49) vs 44.5 939.5 -47), female 63% vs 75%, duration of MS, 6 (1.5-10.5) vs 6 (2-12), EDSS 2.5 (2-4) vs 2 (1-3); PP and SP excluded; McDonald 2001 criteria | High-dose D2 group received 1,000 IU vitamin D2 daily plus a high-dose vitamin D2 supplement for 6 months | | Other: low-dose D2 received 1000 IU vitamin D2 daily plus a placebo | OR for lower exit EDSS comparing high-dose with low-dose: 0.16 (CI 0.02, 1.34, p = 0.09) | N/A

Notes: AE adverse events, Co co-intervention, DMT disease-modifying therapy, N/A not available, R-R relapsing-remitting, PP primary progressive, SP secondary progressive, vs versus

§ All studies are RCTs unless otherwise noted.

We identified 6 RCTs addressing vitamin D supplementation. Studies provided patients with different doses, and some studies explicitly tested high- or low-dose supplementation. Most studies administered vitamin D as a capsule. One study provided intramuscular injections. One study provided vitamin D and calcium.^28^ All but one study compared intervention effects to placebo; 1 study provided the control group with a low-dose supplement.^94^ The duration of interventions ranged from 6 to 24 months.

Samples were small and ranged from 23 to 68 randomized patients. One study^88^ reported a power calculation for EDSS score differences. Two studies reported a power calculation, but for a different outcome, and 3 reported no power calculation; hence, it is unclear whether studies were adequately powered to detect a difference in MS progression. Only one study explicitly reported that the sample included 4 (out of 49) patients in secondary progression^28^ and patients with progressive MS were excluded in 3 of the identified studies. ^67,88,94^

All but one of the identified studies reported mean EDSS scores at the end of the trial for both experimental groups, some together with a statistical significance test for differences between groups. One study reported the proportion of patients completing the trial with increased EDSS, but none of the studies reported on the number of patients who entered progression, or reported on the time to progression. Adverse events were addressed in 4 out of 6 studies: one RCT reported no adverse events; one reported nephrolithiasis but did not specify the group; and 2 studies reported on minor adverse events.

The risk of bias assessment for the individual studies is shown in Appendix C. Studies gave supplements with matching placebos or injections with matching placebo injections, thereby reducing the risk of performance bias.

### Summary of Findings and Quality of Evidence for Key Question 3

Results for KQ3 studies (risk factor modification therapies) are grouped by identified intervention type: exercise, diverse dietary interventions, and vitamin D supplementation.

#### Exercise

Across all identified physical exercise intervention studies, 7 reported post-intervention EDSS scores for both treatment arms. The results are shown in the following forest plot.

Figure 4 Effect of Exercise Interventions on EDSS Scores

None of the individual studies reported a statistically significant effect, and the pooled result also did not provide evidence of statistically significant improvements in EDSS scores for exercise relative to an untreated control group (SMD 0.02; CI -0.40, 0.44; I^2^ 0%; 7 RCTs). However, several studies showed baseline imbalances, where intervention participants had higher EDSS scores than the control group. Using baseline-adjusted data for a sensitivity analysis, the result favored the exercise intervention (SMD -0.19; CI -0.34, -0.03; I^2^ 0; 7 RCTs). There was no indication of publication bias (rank test p = 0.562, regression test p = 0.850).

The quality of the evidence for the result of no difference between exercise interventions and untreated control groups on EDSS scores was downgraded by 2 due to severe study limitations and by 1 due to conflicting results in a sensitivity analysis (imprecision). Our confidence in the evidence summary showing the absence of an effect is limited because most studies were not designed to assess EDSS changes, study sample sizes were very small which could only detect a large treatment effect, and there were baseline imbalances. The intervention duration was not long-term but ranged between 4 weeks and 3 months, which may be too short to achieve, and to detect changes with standard diagnostic criteria. In addition, the difference between intervention and control groups was statistically significant when adjusting for baseline scores; hence an intervention effect in better-designed studies cannot be ruled out. Nonetheless, any treatment effect is likely to be very small; even adjusting for baseline imbalances, the estimate was an average of 0.20 points of improvement on the EDSS scale.

None of the studies reported on other outcome measures such as the change from relapsing-remitting to secondary progressive MS.

#### Dietary Interventions

Across studies, 4 dietary intervention studies reported on the number of patients deteriorating and entering progression in each group. The figure shows that none of the included studies reported a statistically significant effect between fatty acids supplementation compared to placebo. The intervention duration ranged from 18 to 24 months.

The pooled relative risk of experiencing progression was not statistically significantly lower in intervention groups (RR 0.86; CI 0.67, 1.05; I^2^ 0; 4 RCTs). Of note, Bates et al (1977) exclusively addressed patients with chronic progression.^24^

A similar result was shown for differences in EDSS scores between treatment and control groups across 3 dietary intervention studies testing fatty acids supplementation or Hot nature diet advice.

None of the individual interventions demonstrated a statistically significant effect on EDSS scores. Across studies, the difference in EDSS scores was not systematically different between intervention and control groups (SMD -0.13, -83, 0.56; I^2^ 5%; 3 RCTs).

One identified dietary intervention study reported a significant intervention effect, but this study could not be included in the meta-analysis. The study concluded that high-dose treatment of gamma-linolenic acid significantly reduced disability progression compared with placebo and low-dose treatment, but it did not report numerical data.^44^

The quality of evidence for the dietary intervention results showing the absence of an effect on MS progression (measured as the relative risk of progression [see figure 5] or based on EDSS scores [see figure 6]) were both downgraded to moderate due to study limitations. The early studies lack reporting detail while the more recently published studies were small and did not report statistical power calculations to determine whether studies were designed to detect an effect of the intervention on MS progression.

Figure 5 Effect of Fatty Acid Supplementation Interventions on the Relative Risk of Progression

Figure 6 Effect of Dietary Interventions on EDSS Scores

We did not identify studies reporting on other MS progression outcomes such as the time to secondary progression.

#### Vitamin D

The 5 RCTs comparing vitamin D supplementation to placebo and reporting on the same outcome measure are shown in the figure. All reported on EDSS scores.

Figure 7 Effect of Vitamin D Interventions on EDSS Scores

None of the individual studies reported a statistically significant effect of the specific intervention under evaluation. While the pooled result indicated a positive trend, we also could not show a significant difference in EDSS scores between intervention and control group across all studies using standardized mean differences (SMD -0.15; CI -0.33, 0.02; I^2^ 0; 5 RCTs). However, analyzing weighted mean differences to determine the clinical importance of the difference showed a statistically significant effect of vitamin D supplementation on EDSS scores (WMD -0.22; CI -0.39, -0.05; I^2^ 0; 5 RCTs). The result indicates a difference in EDSS scores of 0.22 between intervention and control groups. There was no evidence of publication bias for this result (rank test p = 0.82, regression test p = 0.99).

The quality of evidence for a non-significant effect of vitamin D supplementation on EDSS scores was downgraded by 2 due to study limitations and by 1 due to imprecision. The included studies were small and the lack of reported power calculations makes it unclear whether the studies were sufficiently powered to be able to detect small treatment effects. The statistical significance is dependent on the effect measure, showing that the effect estimate is not very robust.

Studies on vitamin D did not report on other MS progression-relevant outcomes.

#### Summary for KQ3

The following summary of findings table documents the results for all interventions or class of interventions for outcomes that were reported in at least 2 studies.

Table 13 Summary of Findings for KQ3

Intervention Outcome | # of RCTs | Findings: Direction, Magnitude of Effect | GRADE
Exercise Interventions
EDSS score differences | 7 RCTs | No statistically significant difference between exercise intervention and control group (SMD 0.02; CI -0.40, 0.44) | Very low (study limitations,^**^ imprecision^*^)
Dietary Interventions
Number of patients progressing | 4 RCTs | No statistically significant difference between fatty acids supplementation intervention and control group (RR 0.86; CI 0.67, 1.05) | Moderate (study limitations^*^)
EDSS score differences | 3 RCTs | No statistically significant difference between dietary intervention (fatty acids or Hot nature diet) and control group (SMD -0.13; CI -0.83, 0.56) | Moderate (study limitations^*^)
Vitamin D Supplements
EDSS score differences | 5 RCTs | No statistically significant difference between vitamin D supplementation and placebo (SMD -0.15; CI -0.33, 0.02) | Very low (study limitations,^**^ imprecision^*^)

Note:

* quality of evidence downgraded by 1 level,

** quality of evidence downgraded by 2 levels

#### VA Subgroup Analysis

The participants in Lo et al were recruited either from the MS clinic at the VA Connecticut Healthcare System or through chapters of the National Multiple Sclerosis Society.^56^ The study compared body weight supported treadmill training, with or without robot assistance, and found an improvement in EDSS scales for both groups across the 13 participants.

The author affiliation of the study by Yadav et al^110^ suggests that the participants were US Veterans. Patients were assigned to a one year low-fat, plant-based diet. The study reported no significant changes in EDSS scores in the groups after baseline difference adjustment. Only few study details were available; the study was published as a conference abstract.