# REFERENCES

1 Confavreux C, Vukusic S, Moreau T, Adeleine P. (2000). Relapses and progression of disability in multiple sclerosis. N Engl J Med.
2 (2014). Multiple sclerosis - management of multiple sclerosis in primary and secondary care.
3 Veterans Health Administration. (2009). The Office of Patient Care Services: Medical-Surgical Services VHA HANDBOOK 1011.06 Multiple Sclerosis System of Care Procedures.
4 Jagannath VA, Fedorowicz Z, Asokan GV, Robak EW, Whamond L. (2010). Vitamin D for the management of multiple sclerosis. Cochrane Database Syst Rev.
5 Kuhlmann T, Lingfeld G, Bitsch A, Schuchardt J, Bruck W. (2002). Acute axonal damage in multiple sclerosis is most extensive in early disease stages and decreases over time. Brain: a Journal of Neurology.
6 Poser CM, Paty DW, Scheinberg L, et al. (1983). New diagnostic criteria for multiple sclerosis: guidelines for research protocols. Annals of Neurology.
7 McDonald WI, Compston A, Edan G, et al. (2001). Recommended diagnostic criteria for multiple sclerosis: guidelines from the International Panel on the diagnosis of multiple sclerosis. Annals of Neurology.
8 Lublin FD, Reingold SC, Cohen JA, et al. (2014). Defining the clinical course of multiple sclerosis: the 2013 revisions. Neurology.
9 Herndon RM. (2002). Medical hypothesis: why secondary progressive multiple sclerosis is a relentlessly progressive illness. Archives of Neurology.
10 Compston A, Coles A. (2002). Multiple sclerosis. Lancet.
11 D'Hooghe MB, Nagels G, Bissay V, De Keyser J. (2010). Modifiable factors influencing relapses and disability in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
12 Farinotti M, Vacchi L, Simi S, Di Pietrantonj C, Brait L, Filippini G. (2012). Dietary interventions for multiple sclerosis. Cochrane Database Syst Rev.
13 Faridar A, Eskandari G, Sahraian MA, Minagar A, Azimi A. (2012). Vitamin D and multiple sclerosis: a critical review and recommendations on treatment. Acta Neurol Belg.
14 Altman DG. (2001). Systematic reviews of evaluations of prognostic variables. BMJ.
15 Hayden JA, van der Windt DA, Cartwright JL, Cote P, Bombardier C. (2013). Assessing bias in studies of prognostic factors. Annals of Internal Medicine.
16 Kurtzke JF. (1983). Rating neurologic impairment in multiple sclerosis: an expanded disability status scale (EDSS). Neurology.
17 Balshem H, Helfand M, Schunemann HJ, et al. (2011). GRADE guidelines: 3. Rating the quality of evidence. Journal of Clinical Epidemiology.
18 Huguet A, Hayden JA, Stinson J, et al. (2013). Judging the quality of evidence in reviews of prognostic factor research: adapting the GRADE framework. Syst Rev.
19 Armutlu K, Karabudak R, Nurlu G. (2001). Physiotherapy approaches in the treatment of ataxic multiple sclerosis: a pilot study. Neurorehabil Neural Repair.
20 Ascherio A, Munger KL, White R, et al. (2014). Vitamin D as an early predictor of multiple sclerosis activity and progression. JAMA Neurology.
21 Aupperle R, Denney D, Lynch S. (2005). Omega 3 fatty acid levels in multiple sclerosis: correlation of diet, disability, and depression. Multiple Sclerosis.
22 Baghizadeh S, Sahraian MA, Beladimoghadam N. (2013). Clinical and demographic factors affecting disease severity in patients with multiple sclerosis. Iranian Journal of Neurology.
23 Bates D, Cartlidge NE, French JM, et al. (1989). A double-blind controlled trial of long chain n-3 polyunsaturated fatty acids in the treatment of multiple sclerosis. Journal of Neurology, Neurosurgery, and Psychiatry.
24 Bates D, Fawcett PR, Shaw DA, Weightman D. (1977). Trial of polyunsaturated fatty acids in non-relapsing multiple sclerosis. British Medical Journal.
25 Bates D, Fawcett PR, Shaw DA, Weightman D. (1978). Polyunsaturated fatty acids in treatment of acute remitting multiple sclerosis. British Medical Journal.
26 Bjarnadottir OH, Konradsdottir AD, Reynisdottir K, Olafsson E. (2007). Multiple sclerosis and brief moderate exercise. A randomised study. Multiple sclerosis (Houndmills, Basingstoke, England).
27 Bombardier CH, Blake KD, Ehde DM, Gibbons LE, Moore D, Kraft GH. (2004). Alcohol and drug abuse among persons with multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
28 Burton JM, Kimball S, Vieth R, et al. (2010). A phase I/II dose-escalation trial of vitamin D3 and calcium in multiple sclerosis. Neurology.
29 Carter AM, Daley AJ, Kesterton SW, Woodroofe NM, Saxton JM, Sharrack B. (2013). Pragmatic exercise intervention in people with mild to moderate multiple sclerosis: a randomised controlled feasibility study. Contemporary Clinical Trials.
30 Confavreux C, Hutchinson M, Hours MM, Cortinovis-Tourniaire P, Moreau T. (1998). Rate of pregnancy-related relapse in multiple sclerosis. Pregnancy in Multiple Sclerosis Group. N Engl J Med.
31 Conklyn D, Stough D, Novak E, Paczak S, Chemali K, Bethoux F. (2010). A home-based walking program using rhythmic auditory stimulation improves gait performance in patients with multiple sclerosis: a pilot study. Neurorehabil Neural Repair.
32 Dalgas U, Stenager E, Jakobsen J, et al. (2009). Resistance training improves muscle strength and functional capacity in multiple sclerosis. Neurology.
33 Dastagir A, Alqallaf A, Bao F, et al. (2013). Vitamin D Levels in African-Americans and Caucasian with Relapsing Multiple Sclerosis: Relationship with Disease Course. Neurology.
34 DeBolt LS, McCubbin JA. (2004). The effects of home-based resistance exercise on balance, power, and mobility in adults with multiple sclerosis. Archives of Physical Medicine and Rehabilitation.
35 Detels R, Clark VA, Valdiviezo NL, Visscher BR, Malmgren RM, Dudley JP. (1982). Factors associated with a rapid course of multiple sclerosis. Archives of Neurology.
36 D'Hooghe M B, Haentjens P, Nagels G, De Keyser J. (2012). Alcohol, coffee, fish, smoking and disease progression in multiple sclerosis. European Journal of Neurology:The Official Journal of the European Federation of Neurological Societies.
37 Fimland MS, Helgerud J, Gruber M, Leivseth G, Hoff J. (2010). Enhanced neural drive after maximal strength training in multiple sclerosis patients. European Journal of Applied Physiology.
38 Foster M, Zivadinov R, Weinstock-Guttman B, et al. (2012). Associations of moderate alcohol consumption with clinical and MRI measures in multiple sclerosis. Journal of Neuroimmunology.
39 Fragoso YD, Adoni T, Almeida SM, et al. (2013). Multiple sclerosis in South America: month of birth in different latitudes does not seem to interfere with the prevalence or progression of the disease. Arq Neuropsiquiatr.
40 Gava G, Bartolomei I, Costantino A, et al. (2014). Long-term influence of combined oral contraceptive use on the clinical course of relapsing-remitting multiple sclerosis. Fertility and Sterility.
41 Gelfand JM, Cree BAC, McElroy J, et al. (2011). Vitamin D in African Americans with multiple sclerosis. Neurology.
42 Golzari Z, Shabkhiz F, Soudi S, Kordi MR, Hashemi SM. (2010). Combined exercise training reduces IFN-gamma and IL-17 levels in the plasma and the supernatant of peripheral blood mononuclear cells in women with multiple sclerosis. Int Immunopharmacol.
43 Goodin DS. (1999). Survey of multiple sclerosis in northern California. Northern California MS Study Group. Multiple sclerosis (Houndmills, Basingstoke, England).
44 Harbige LS, Sharief MK. (2007). Polyunsaturated fatty acids in the pathogenesis and treatment of multiple sclerosis. The British Journal of Nutrition.
45 Hatamian H, Bidabadi E, Seyed Saadat SM, et al. (2013). Is serum vitamin D levels associated with disability in patients with newly diagnosed multiple sclerosis?. Iranian Journal of Neurology.
46 Healy BC, Ali EN, Guttmann CR, et al. (2009). Smoking and disease progression in multiple sclerosis. Archives of Neurology.
47 Hernan MA, Jick SS, Logroscino G, Olek MJ, Ascherio A, Jick H. (2005). Cigarette smoking and the progression of multiple sclerosis. Brain: a Journal of Neurology.
48 Jansons L, Tutuncu M, Tang J, et al. (2011). Does smoking really impact progression in multiple sclerosis?. Mult Scler J.
49 Kampman MT, Steffensen LH, Mellgren SI, Jorgensen L. (2012). Effect of vitamin D3 supplementation on relapses, disease progression, and measures of function in persons with multiple sclerosis: exploratory outcomes from a double-blind randomised controlled trial. Multiple Sclerosis (Houndmills, Basingstoke, England).
50 Knippenberg S, Bol Y, Damoiseaux J, Hupperts R, Smolders J. (2011). Vitamin D status in patients with MS is negatively correlated with depression, but not with fatigue. Acta Neurologica Scandinavica.
51 Koch M, De Keyser J, Tremlett H. (2008). Timing of birth and disease progression in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
52 Koch M, van Harten A, Uyttenboogaart M, De Keyser J. (2007). Cigarette smoking and progression in multiple sclerosis. Neurology.
53 Kragt J, van Amerongen B, Killestein J, et al. (2009). Higher levels of 25-hydroxyvitamin D are associated with a lower incidence of multiple sclerosis only in women. Multiple Sclerosis (Houndmills, Basingstoke, England).
54 Kurtzke JF, Beebe GW, Nagler B, Auth TL, Kurland LT, Nefzger MD. (1973). Studies on the natural history of multiple sclerosis. 7. Correlates of clinical change in an early bout. Acta Neurologica Scandinavica.
55 Lauer K, Firnhaber W. (1992). Prognostic criteria in an epidemiological group of patients with multiple sclerosis: an exploratory study. Journal of Neurology.
56 Lo AC, Triche EW. (2008). Improving gait in multiple sclerosis using robot-assisted, body weight supported treadmill training. Neurorehabil Neural Repair.
57 Lu E, Zhao Y, Dahlgren L, et al. (2013). Obstetrical epidural and spinal anesthesia in multiple sclerosis. Journal of Neurology.
58 Lucenti A, Galimberti S, Barizzone N, et al. (2014). Multiple sclerosis progression is not associated with birth timing in Italy. Journal of the Neurological Sciences.
59 Maghzi AH, Etemadifar M, Heshmat-Ghahdarijani K, et al. (2011). Cigarette smoking and the risk of multiple sclerosis: a sibling case-control study in Isfahan, Iran. Neuroepidemiology.
60 Mandia D, Ferraro OE, Nosari G, Montomoli C, Zardini E, Bergamaschi R. (2014). Environmental Factors and Multiple Sclerosis Severity: A Descriptive Study. Int J Environ Res Public Health.
61 Manouchehrinia A, Tench CR, Maxted J, Bibani RH, Britton J, Constantinescu CS. (2013). Tobacco smoking and disability progression in multiple sclerosis: United Kingdom cohort study. Brain: a Journal of Neurology.
62 Marrie R, Horwitz R, Cutter G, Tyry T, Campagnolo D, Vollmer T. (2009). High frequency of adverse health behaviors in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
63 McDowell TY, Amr S, Culpepper WJ, et al. (2011). Sun exposure, vitamin D intake and progression to disability among veterans with progressive multiple sclerosis. Neuroepidemiology.
64 Milivojevic I, Adamec I, Habek M. (2013). Utilization of physical rehabilitation among people with multiple sclerosis. Irish Journal of Medical Science.
65 Millar JH, Zilkha KJ, Langman MJ, et al. (1973). Double-blind trial of linoleate supplementation of the diet in multiple sclerosis. British Medical Journal.
66 Miller L, Paul L, Mattison P, McFadyen A. (2011). Evaluation of a home-based physiotherapy programme for those with moderate to severe multiple sclerosis: a randomized controlled pilot study. Clin Rehabil.
67 Mosayebi G, Ghazavi A, Ghasami K, Jand Y, Kokhaei P. (2011). Therapeutic effect of vitamin D3 in multiple sclerosis patients. Immunological Investigations.
68 Motl RW, Dlugonski D, Pilutti L, Sandroff B, McAuley E. (2012). Premorbid physical activity predicts disability progression in relapsing-remitting multiple sclerosis. Journal of the Neurological Sciences.
69 Mowry EM, Waubant E, McCulloch CE, et al. (2012). Vitamin D status predicts new brain magnetic resonance imaging activity in multiple sclerosis. Annals of Neurology.
70 Niino M, Fukazawa T, Miyazaki Y, et al. (2013). Association of serum vitamin D levels in Japanese patients with multiple sclerosis. Clinical and Experimental Neuroimmunology.
71 Pantzaris MC, Loukaides GN, Ntzani EE, Patrikios IS. (2013). A novel oral nutraceutical formula of omega-3 and omega-6 fatty acids with vitamins (PLP10) in relapsing remitting multiple sclerosis: a randomised, double-blind, placebo-controlled proof-of-concept clinical trial. BMJ open.
72 Pasto L, Portaccio E, Ghezzi A, et al. (2012). Epidural analgesia and cesarean delivery in multiple sclerosis post-partum relapses: the Italian cohort study. BMC Neurol.
73 Paty DW, Cousin HK, Read S, Adlakha K. (1978). Linoleic acid in multiple sclerosis: failure to show any therapeutic benefit. Acta Neurologica Scandinavica.
74 Petajan JH, Gappmaier E, White AT, Spencer MK, Mino L, Hicks RW. (1996). Impact of aerobic training on fitness and quality of life in multiple sclerosis. Annals of Neurology.
75 Pfalzer L, Fry D. (2011). Effects of a 10-week inspiratory muscle training program on lower-extremity mobility in people with multiple sclerosis: a randomized controlled trial. International Journal of MS care.
76 Pittas F, Ponsonby AL, van der Mei IA, et al. (2009). Smoking is associated with progressive disease course and increased progression in clinical disability in a prospective cohort of people with multiple sclerosis. Journal of Neurology.
77 Plow M, Finlayson M, Cho C. (2012). Correlates of nutritional behavior in individuals with multiple sclerosis. Disabil Health J.
78 Ramirez-Ramirez V, Macias-Islas MA, Ortiz GG, et al. (2013). Efficacy of fish oil on serum of TNF alpha , IL-1 beta , and IL-6 oxidative stress markers in multiple sclerosis treated with interferon beta-1b. Oxidative Medicine and Cellular Longevity.
79 Rampello A, Franceschini M, Piepoli M, et al. (2007). Effect of aerobic training on walking capacity and maximal exercise tolerance in patients with multiple sclerosis: a randomized crossover controlled study. Physical Therapy.
80 Rezapour-Firouzi S, Arefhosseini SR, Ebrahimi-Mamaghani M, et al. (2013). Erythrocyte membrane fatty acids in multiple sclerosis patients and hot-nature dietary intervention with co-supplemented hemp-seed and evening-primrose oils. African Journal of Traditional, Complementary, and Alternative medicine: AJTCAM / African Networks on Ethnomedicines.
81 Romberg A, Virtanen A, Ruutiainen J, et al. (2004). Effects of a 6-month exercise program on patients with multiple sclerosis: a randomized study. Neurology.
82 Roudbari SA, Ansar MM, Yousefzad A. (2013). Smoking as a risk factor for development of Secondary Progressive Multiple Sclerosis: A study in IRAN, Guilan. Journal of the Neurological Sciences.
83 Sangelaji B, Nabavi SM, Estebsari F, et al. (2014). Effect of combination exercise therapy on walking distance, postural balance, fatigue and quality of life in multiple sclerosis patients: a clinical trial study. Iranian Red Crescent Medical Journal.
84 Schwartz I, Sajin A, Moreh E, et al. (2012). Robot-assisted gait training in multiple sclerosis patients: a randomized trial. Multiple Sclerosis (Houndmills, Basingstoke, England).
85 Sena A, Couderc R, Vasconcelos JC, Ferret-Sena V, Pedrosa R. (2012). Oral contraceptive use and clinical outcomes in patients with multiple sclerosis. Journal of the Neurological Sciences.
86 Shahbeigi S, Pakdaman H, Fereshtehnejad SM, Nikravesh E, Mirabi N, Jalilzadeh G. (2013). Vitamin d3 concentration correlates with the severity of multiple sclerosis. International Journal of Preventive Medicine.
87 Shammas L, Zentek T, von Haaren B, Schlesinger S, Hey S, Rashid A. (2014). Home-based system for physical activity monitoring in patients with multiple sclerosis (Pilot study). Biomedical Engineering Online.
88 Shaygannejad V, Janghorbani M, Ashtari F, Dehghan H. (2012). Effects of adjunct low-dose vitamin d on relapsing-remitting multiple sclerosis progression: preliminary findings of a randomized placebo-controlled trial. Multiple Sclerosis International.
89 Sibley WA, Bamford CR, Clark K, Smith MS, Laguna JF. (1991). A prospective study of physical trauma and multiple sclerosis. Journal of Neurology, Neurosurgery, and Psychiatry.
90 Smolders J, Menheere P, Kessels A, Damoiseaux J, Hupperts R. (2008). Association of vitamin D metabolite levels with relapse rate and disability in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
91 Soilu-Hanninen M, Laaksonen M, Laitinen I, Eralinna JP, Lilius EM, Mononen I. (2008). A longitudinal study of serum 25-hydroxyvitamin D and intact parathyroid hormone levels indicate the importance of vitamin D and calcium homeostasis regulation in multiple sclerosis. Journal of Neurology, Neurosurgery, and Psychiatry.
92 Solari A, Filippini G, Gasco P, et al. (1999). Physical rehabilitation has a positive effect on disability in multiple sclerosis patients. Neurology.
93 Spitzer C, Bouchain M, Winkler LY, et al. (2012). Childhood trauma in multiple sclerosis: a case-control study. Psychosomatic Medicine.
94 Stein MS, Liu Y, Gray OM, et al. (2011). A randomized trial of high-dose vitamin D2 in relapsing-remitting multiple sclerosis. Neurology.
95 Sternberg Z, Leung C, Sternberg D, et al. (2013). The prevalence of the classical and non-classical cardiovascular risk factors in multiple sclerosis patients. CNS & Neurological Disorders Drug Targets.
96 Stuifbergen AK, Blozis SA, Harrison TC, Becker HA. (2006). Exercise, functional limitations, and quality of life: A longitudinal study of persons with multiple sclerosis. Archives of Physical Medicine and Rehabilitation.
97 Sundstrom P, Nystrom L. (2008). Smoking worsens the prognosis in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
98 Swank RL, Dugan BB. (1990). Effect of low saturated fat diet in early and late cases of multiple sclerosis. Lancet.
99 Teter B, Weinstock-Guttman B, Mihai C, et al. (2008). Parity, education and sun exposure may predict long-term disability in female patients with multiple sclerosis. Multiple Sclerosis.
100 Thouvenot E, Orsini M, Daures JP, Camu W. (2015). Vitamin D is associated with degree of disability in patients with fully ambulatory relapsing-remitting multiple sclerosis. European Journal of Neurology: The Official Journal of the European Federation of Neurological Societies.
101 Torkildsen O, Wergeland S, Bakke S, et al. (2012). omega-3 fatty acid treatment in multiple sclerosis (OFAMS Study): a randomized, double-blind, placebo-controlled trial. Archives of Neurology.
102 Tuzun E, Polat A, Akman-Demir G, et al. (2010). Impact of Earthquake on Multiple Sclerosis Attacks. Noropsikiyatri Ars.
103 van der Mei IA, Ponsonby AL, Dwyer T, et al. (2007). Vitamin D levels in people with multiple sclerosis and community controls in Tasmania, Australia. Journal of Neurology.
104 Vollmer TL, Hadjimichael O, Preiningerova J, Ni W, Buenconsejo J. (2002). Disability and treatment patterns of multiple sclerosis patients in United States: a comparison of veterans and nonveterans. Journal of Rehabilitation Research and Development.
105 Wallin M, Culpepper WJ, Kurtzke J. (2015). Risk Factors for Disease Progression in a Diverse US Population-based Multiple Sclerosis Cohort (S45.003). Neurology.
106 Weiland TJ, Hadgkiss EJ, Jelinek GA, Pereira NG, Marck CH, van der Meer DM. (2014). The association of alcohol consumption and smoking with quality of life, disability and disease activity in an international sample of people with multiple sclerosis. Journal of the Neurological Sciences.
107 Weinstock-Guttman B, Baier M, Park Y, et al. (2005). Low fat dietary intervention with omega-3 fatty acid supplementation in multiple sclerosis patients. Prostaglandins, Leukotrienes, and Essential Fatty Acids.
108 Weinstock-Guttman B, Zivadinov R, Ramanathan M. (2011). Inter-dependence of vitamin D levels with serum lipid profiles in multiple sclerosis. Journal of the Neurological Sciences.
109 Wiles CM, Newcombe RG, Fuller KJ, et al. (2001). Controlled randomised crossover trial of the effects of physiotherapy on mobility in chronic multiple sclerosis. Journal of Neurology, Neurosurgery, and Psychiatry.
110 Yadav V, Marracci G, Kim E, et al. (2014). Effects of a low fat plant based diet in multiple sclerosis (MS): Results of a 1-year long randomized controlled (RC) study. Neurology.
111 Zivadinov R, Weinstock-Guttman B, Hashmi K, et al. (2009). Smoking is associated with increased lesion volumes and brain atrophy in multiple sclerosis. Neurology.
112 Tepavcevic DK, Kostic J, Stojsavljevic N, et al. (2010). Cigarette smoking as a predictor for change in disability in multiple sclerosis patients: a 6-year follow-up study in Belgrade (Serbia). European Journal of Neurology.
113 Runmarker B, Andersen O. (1995). Pregnancy is associated with a lower risk of onset and a better prognosis in multiple sclerosis. Brain: A Journal of Neurology.
114 Brandes DW, Bigley K, Hornstein W, Cohen H, Au W, Shubin R. (2007). Alleviating flu-like symptoms with dose titration and analgesics in MS patients on intramuscular interferon beta-1a therapy: a pilot study. Curr Med Res Opin.
115 Maciejek Z, Wojcik-Draczkowska H, Wawrzyniak S, Niezgodzinska-Maciejek A. (2013). Evaluation of efficacy, safety and tolerability of fingolimod in patients with the relapsing form of multiple sclerosis - 12-month observation. A preliminary report. Neurologia i Neurochirurgia Polska.
116 Vukusic S, Hutchinson M, Hours M, et al. (2004). Pregnancy and multiple sclerosis (the PRIMS study): clinical predictors of post-partum relapse. Brain: A Journal of Neurology.
117 Tavee J, Rensel M, Planchon SM, Butler RS, Stone L. (2011). Effects of meditation on pain and quality of life in multiple sclerosis and peripheral neuropathy: a pilot study. International Journal of MS Care.
118 Swank RL, Goodwin J. (2003). Review of MS patient survival on a Swank low saturated fat diet. Nutrition.
119 Swank RL. (1991). Multiple sclerosis: fat-oil relationship. Nutrition.
120 D'Hooghe MB, Haentjens P, Nagels G, Garmyn M, De Keyser J. (2012). Sunlight exposure and sun sensitivity associated with disability progression in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
121 D'Hooghe MB, Haentjens P, Nagels G, D'Hooghe T, De Keyser J. (2012). Menarche, oral contraceptives, pregnancy and progression of disability in relapsing onset and progressive onset multiple sclerosis. Journal of Neurology.
122 D'Hooghe MB, Nagels G, De Keyser J, Haentjens P. (2013). Self-reported health promotion and disability progression in multiple sclerosis. Journal of the Neurological Sciences.
123 Marck CH, Hadgkiss EJ, Weiland TJ, van der Meer DM, Pereira NG, Jelinek GA. (2014). Physical activity and associated levels of disability and quality of life in people with multiple sclerosis: a large international survey. BMC Neurol.
124 Levin AB, Hadgkiss EJ, Weiland TJ, et al. (2014). Can meditation influence quality of life, depression, and disease outcome in multiple sclerosis? Findings from a large international web-based study. Behavioural Neurology.
125 Thomas S, Thomas PW, Kersten P, et al. (2013). A pragmatic parallel arm multi-centre randomised controlled trial to assess the effectiveness and cost-effectiveness of a group-based fatigue management programme (FACETS) for people with multiple sclerosis. Journal of Neurology, Neurosurgery, and Psychiatry.
126 Zajicek J, Fox P, Sanders H, et al. (2003). Cannabinoids for treatment of spasticity and other symptoms related to multiple sclerosis (CAMS study): multicentre randomised placebo-controlled trial. Lancet.
127 Solari A, Motta A, Mendozzi L, et al. (2004). Computer-aided retraining of memory and attention in people with multiple sclerosis: a randomized, double-blind controlled trial. Journal of the Neurological Sciences.
128 Soilu-Hanninen M, Aivo J, Lindstrom BM, et al. (2012). A randomised, double blind, placebo controlled trial with vitamin D3 as an add on treatment to interferon beta-1b in patients with multiple sclerosis. Journal of Neurology, Neurosurgery, and Psychiatry.
129 Pozuelo-Moyano B, Benito-Leon J, Mitchell AJ, Hernandez-Gallego J. (2013). A systematic review of randomized, double-blind, placebo-controlled trials examining the clinical efficacy of vitamin D in multiple sclerosis. Neuroepidemiology.
130 Handel AE, Williamson AJ, Disanto G, Dobson R, Giovannoni G, Ramagopalan SV. (2011). Smoking and multiple sclerosis: an updated meta-analysis. PloS One.
131 Rietberg MB, Brooks D, Uitdehaag BMJ, Kwakkel G. (2005). Exercise therapy for multiple sclerosis - art. no. CD003980.pub2. Cochrane Database Syst Rev.
132 Feinstein A, Dalgas U. (2014). The benefits of exercise in progressive MS: some cautious optimism. Multiple Sclerosis (Houndmills, Basingstoke, England).
133 Dalgas U, Stenager E. (2012). Exercise and disease progression in multiple sclerosis: can exercise slow down the progression of multiple sclerosis?. Therapeutic Advances in Neurological Disorders.
134 Sa MJ. (2014). Exercise therapy and multiple sclerosis: a systematic review. Journal of Neurology.
135 Marrie RA, Hanwell H. (2013). General health issues in multiple sclerosis: comorbidities, secondary conditions, and health behaviors. Continuum (Minneapolis, Minn.).
136 Overs S, Hughes CM, Haselkorn JK, Turner AP. (2012). Modifiable comorbidities and disability in multiple sclerosis. Current Neurology and Neuroscience reports.
137 Miller DH, Fazekas F, Montalban X, Reingold SC, Trojano M. (2014). Pregnancy, sex and hormonal factors in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).