# METHODS

## TOPIC DEVELOPMENT

This topic was developed in response to a nomination by the VA Multiple Sclerosis Center of Excellence-East, for an evidence review to examine the role of modifiable risk factors and military exposures in the progression of MS, as well as methods to reduce progression that are directed at modifiable risk factors.

The Key Questions (KQ) were:

1. What modifiable epidemiologic factors are related to multiple sclerosis progression following diagnosis?
2. What environmental exposures prior to or during military service are related to multiple sclerosis progression following onset symptoms?
3. Among identified risk factors for progression, what treatment/risk factor modification therapies have been shown to delay or hasten the progression of multiple sclerosis once it has initiated?

## SEARCH STRATEGY

We searched the electronic databases PubMed (medical literature); EMBASE (biomedical literature); AMED (Allied and Complementary Medicine Database); SCOPUS and Web of Science (broad research databases indexing conference papers and innovations); GreenFILE (environmental factors); DTIC (Defense Technical Information Center), and ProQuest Military Collection (databases for military research) for primary research studies published in English to March 2015 without date restriction. Dates of database inception varied; for example, PubMed systematically indexes research published since 1966, with some earlier publications.

For KQ1, we employed a search strategy that combined known presumed risk factors, and a more general search for prognostic study designs based on a published search filter^14^ applied to PubMed, SCOPUS, Web of Science, and GreenFILE.

The KQ2 search strategy used search terms for military populations to identify MS studies without further study restrictions in the databases PubMed, EMBASE, AMED, SCOPUS, Web of Science, GreenFILE, DTIC, and ProQuest Military Collection.

For KQ3 we applied a search filter for randomized controlled trials (RCTs) to search the databases PubMed, AMED, SCOPUS, and Web of Science, to target eligible studies. The PubMed search encompassed all indexed RCTs in MS patients and was not restricted to a set of pre-defined interventions, to avoid missing relevant studies targeting uniquely-named or novel interventions.

Furthermore, we screened references of pertinent reviews and consulted with topic experts to ensure that all relevant studies were identified.

## STUDY SELECTION

Two independent reviewers screened titles and abstracts of retrieved citations and recorded decisions in an electronic database. Citations deemed potentially relevant by at least one of the reviewers were obtained as full text. The full-text publications were screened against the specified inclusion criteria by 2 independent literature reviewers; disagreements were resolved through discussion within the review team. The literature flow was documented in an electronic database and reasons for exclusion of full text publications were recorded.

To be included in the systematic review, studies had to meet the following criteria, organized in the PICOTS framework.

Participants: Studies in human adult participants with a clinical diagnosis of MS were eligible for inclusion for KQ1 and KQ3. KQ2 was limited to active military personnel and Veterans with MS. Studies exclusively focusing on pediatric MS in children and adolescents were excluded. Studies targeting a range of clinical conditions were included as long as data on MS progression was reported separately. The sample composition of MS populations was not restricted but risk factor studies excluding all progressive forms and not reporting on MS progression were excluded (eg, studies describing disease severity in explicitly non-progressive forms).

Intervention: Studies reporting on modifiable epidemiologic factors and environmental exposures potentially associated with MS progression (“risk factors”) were eligible for inclusion for KQ1 and KQ2. Eligible risk factors included (but were not limited to) the geographic region of residence, sun exposure, vitamin D intake, polyunsaturated fatty acid intake, diet, smoking, alcohol, exercise behavior, vaccinations, anesthesia exposure, radiation therapy exposure, use of oral contraception, fertility treatment, childbirth delivery variables, breastfeeding, salt intake, use of milk products, water sources intake, trace elements intake, mercury exposure, trauma exposure, military service/deployment, and military exposures. Non-modifiable risk factors such as genetic predispositions, physiological correlates, or demographic characteristics at MS onset were excluded. Descriptive factors such as quality of life or vitality with unclear modifiability, comorbidities, and concurrent psychological correlates of disability status that are more likely to be a reaction to than a predictor of MS (eg, coping strategies and perceptions of body image) were excluded. Factors directly associated with known MS medication, such as the use of disease-modifying treatment, type of medication, medication combinations, dosing schemes, adherence, and timing of therapy onset were also excluded.

Intervention studies evaluating the effect of modifying the intake or exposure to potential risk factors (eg, smoking cessation, weight loss, or exercise programs; nutritional interventions targeting vitamin D or Omega-3), alone or in combination with other therapies, were eligible for KQ3. Treatment studies testing potential risk factors were eligible for inclusion regardless of the current strength of association in empirical studies, but studies evaluating unspecific interventions not associated with potential or identified MS risk factors (eg, acupuncture) were excluded. Treatment studies evaluating the effect of existing, FDA-approved MS medications that aim to modify the disease course of MS (eg, interferon beta-1a), or aim to manage MS relapses (eg, prednisone), other suggested medication for MS (eg, laquinimod), treatments for autoimmune and immunodeficiency diseases (eg, corticosteroids), and medication given for their immunomodulatory properties (eg, statins) or tested for their use in MS (eg, lithium) were excluded regardless of any underlying risk factor hypotheses (eg, infection, hygiene hypothesis).

Comparator (design): Observational studies (eg, case-control, cohort studies comparing 2 cohorts, or cross-sectional studies including surveys), and experimental studies analyzing factors associated with MS progression were eligible for KQ1 and KQ2. Non-randomized experimental studies had to have a non-treated concurrent control group to identify standard progression rates and provide a power calculation to determine a priori whether differences between experimental groups could be identified. Risk factor studies had to report data on 10 or more participants with MS. Case studies speculating about associations were excluded.

RCTs in adults regardless of the comparator were eligible for KQ3. Only primary research studies were eligible for inclusion. Pertinent reviews and secondary data analyses were retained as background paper for reference mining.

Outcome: Studies reporting on the progression of MS were eligible for inclusion in the review. The primary outcome was Expanded Disability Status Scale (EDSS) scores or progression classifications based on EDSS score cut-offs. Studies reporting on earlier versions of the EDSS scale; other global patient-centered, clinical MS progression measures (eg, Multiple Sclerosis Functional Composite [MSFC], multiple domain assessments of the Functional System Score [FSS], Patient Determined Disability Scale [PDDS]); the clinical course of MS (eg, progression defined by clinical judgment, time to secondary progression); or comparing MS subgroups relevant to progression (eg, relapsing-remitting versus secondary-progressive stage) were eligible for inclusion. Studies reporting on disability measures focusing on the general ability to walk (eg, MS Progression: Disease Steps [DS]) were included. Studies only reporting on individual characteristics of walking (eg, gait, muscle strength, speed) were excluded. Studies reporting on other individual symptoms (eg, fatigue or depression) or individual diagnostic markers (eg, lesions shown with imaging techniques) without reporting on patient outcomes of MS progression were excluded. Studies reporting disability measures not specific to MS (eg, receiving a disability pension) were excluded. Studies reporting on MS-associated mortality were included if the endpoint was part of a continuum of progression and not an incidence measure of MS. Studies reporting on all-cause mortality in MS patient samples, for example investigating whether associations between epidemiologic factors and mortality found in the general population (‘smoking predicts mortality’) also apply to the MS population, were excluded. Studies exclusively reporting on the onset, rather than the progression of MS, and studies only reporting on the prevalence and incidence of MS without differentiating MS subtypes relevant to MS progression (eg, primary progressive MS) were excluded.

Timing: Risk factor studies were not limited by exposure duration and timing (eg, childhood exposure) and any follow-up points were eligible for inclusion in KQ1, but investigator-initiated exposures (ie, interventions) were restricted to long-term interventions if they did not report a statistical power calculation indicating that the study had sufficient power to show a difference between exposed groups. We included prospective (measuring the exposure before the outcome), retrospective (measuring the exposure of a past event retrospectively at the time of measuring the outcome), and concurrent (measuring the exposure status and the outcome at the same time point) studies. Studies eligible for KQ2 were limited to exposures prior to or during military service. Intervention RCTs including any intervention duration, regardless of the intervention timing, and any follow-up points were eligible for inclusion for KQ3.

Setting: Studies of any settings were eligible for inclusion in the review.

Other limiters: English-language studies were included.

The review was registered in PROSPERO, the international registry for systematic reviews PROSPERO http://www.crd.york.ac.uk/PROSPERO/. (PROSPERO 2015:CRD42015016461)

### Protocol Deviations

Due to the overwhelming size of the literature identified through our literature searches that exceeded the available time and resources needed to complete the project, we removed comorbidities such as stress, anxiety, depression, infections, sleep problems, or obesity regardless of their treatability and modifiability status from the eligibility criteria. We also excluded the large body of literature on pregnancy and parity given that the decision to have children may be directly associated with disease severity and anticipated progression (reverse causality is discussed in more detail in the discussion section). Finally, we excluded studies that reported on the physiological or clinical status of patients, such as body weight or serum fatty acid levels, without information on the intake or patient behavior (eg, diet regime) other than vitamin D. In sum, we excluded factors that could either be a reaction to, an independent comorbidity, or a predictor of MS progression, and concentrated primarily on behavior and choices or exposures somewhat under the control of the patient or their families.

## DATA ABSTRACTION

Studies underwent standardized abstraction of study-level data in an electronic database. Data collection forms were designed by the project lead and discussed in the review team.

For KQ1 (risk factors) studies, we extracted information on the MS population (eg, proportion of patients with relapsing-remitting, secondary progressive, or primary progressive MS; age; % male; race/ethnicity distribution). We documented the number of participants in the study sample and the number of cases (ie, patients with progressive MS). We recorded the geographic region of the sample. We documented the study design (eg, cohort study), methods used to analyze the results (eg, linear mixed effects model, partial correlations), and the predictive timeframe (concurrent, retrospective, prospective data). We extracted analyzed, potential, modifiable risk factors of interest together with the time of exposure (eg, alcohol consumption in last 2 years). We recorded all independent variables entering the prediction model. We extracted the point estimate of effects and statistical significance of risk factors on MS progression. The evidence table differentiates predictions for EDSS scores and other clinical course characteristics relevant to MS progression.

Concurrent studies were defined as measuring the exposure status and the outcome at the same time point, such as current alcohol intake. Retrospective studies assessed at least some outcomes retrospectively (eg, cod liver oil consumption during childhood). Prospective studies had to report on at least 2 different points in time assessing the risk factor prior to the MS progression outcome to be classified as prospective.

For studies relevant to KQ2 (military service exposures), we extracted the information on the study population including: MS characteristics and military service status; number of study participants and cases, geographic region; study design; analytic method; assessed prior or post military service exposures; assessed military service exposures; other analyzed independent variables; predictive time frame; EDSS score results; and other clinical course results.

For intervention studies (KQ3, risk factor modification therapies), we extracted the study design and methodological characteristics, number of randomized participants per intervention group and proportion of participants with progressive MS, characteristics of participants, intervention components and co-interventions, comparator details, outcomes, followup points, statistical power analysis, EDSS results, other disease progression results, and adverse events.

Some studies were reported on in more than one publication. Studies, defined by the included participants, were only counted once, regardless of the number of publications the results were published in. The data extraction considered data from all publications available for the study.

## QUALITY ASSESSMENT

For KQ1 and KQ2 we distinguished concurrent, retrospective, and prospective studies. Prospective studies were assessed with QUIPS (Quality In Prognosis Studies), a critical appraisal tool for prognostic studies.^15^

Intervention studies (KQ3) were assessed with the Cochrane risk of bias tool assessing selection bias, performance bias, detection bias, attrition bias, reporting bias, and other sources of bias (where appropriate).

Quality criteria definitions and scoring guidelines for all domains are documented in Appendix C together with the assessment results.

## DATA SYNTHESIS AND ANALYSIS

The evidence tables provide information on each included study to allow a comprehensive overview. Summary of findings tables summarize results for analyzed modifiable risk factor in the general population (KQ1) and military samples (KQ2), and results for individual interventions (KQ3) across all identified studies.

The evidence tables and summary of findings tables differentiated results based on EDSS scores, the primary outcome of the review, and other MS progression results. The EDSS^16^ is widely used to assess the disability and the progression of MS. Scores range from 1 (no disability) to 10 (death due to MS). A milestone often used in research is EDSS 6, characterized by the need for a cane or other constant assistance to walk 100 meters.

Where possible, variables were pooled across studies in meta-analyses to identify reliable and valid effects across studies. We pooled studies where at least 3 studies were available for the risk factor of interest and the effect measure of interest (eg, correlations, time to event data, count data). Continuous outcomes were reported as standardized mean differences (SMD) to facilitate the comparison of effect sizes across outcome measures. We calculated weighted mean differences (WMD) to determine the clinical importance of the effect for studies reporting on the primary outcome EDSS scores. Dichotomous data were presented as relative risks (RR). For time to event data we computed hazard ratios (HR). Correlations (r) transformed to z statistics (using the Fisher transformation) to pool across studies. Point estimates were calculated together with the 95 percent confidence interval (CI). We used a restricted maximum-likelihood estimator and the Hartung-Knapp-Sidik-Jonkman method for random-effects models to pool across studies.

All studies relevant to KQ1 were summarized narratively. When at least 3 studies were available that reported on the same risk factor and the same outcome measure, we performed meta-analysis. The synthesis differentiated variables assessed as potential risk factors, and results indicating a statistically significant association with MS disability and progression. The synthesis addressed negative and positive associations indicating worsening of progression status or protective factors. In addition, it also documented the absence of associations.

Due to the diversity in study designs, analytic methods, and effect measures, and the small number of studies, studies in military personnel and Veterans relevant to KQ2 were summarized narratively. We differentiated assessed variables and statistically significant effects. The narrative synthesis emphasizes risk factors identified in more than one individual study.

Intervention studies (KQ3) were summarized narratively, grouped by intervention category. When at least 3 studies were available for the same intervention group and outcome measure (eg, EDSS scores, number of patients progressing, time to progression), we performed meta-analysis. Data were based on intention-to-treat results, where available. For continuous outcomes results were based on unadjusted post-intervention scores. Results of studies in military personnel and Veterans were an a priori planned subgroup analysis.

## RATING THE BODY OF EVIDENCE

We rated the quality of the evidence for individual risk factors across all identified studies (KQ1), in military and Veteran populations (KQ2), and for individual interventions (KQ3) across all identified pertinent studies. Based on GRADE guidelines^17^ the quality of the evidence was categorized as follows:

High: We are very confident that the true effect lies close to that of the estimate of the effect.

Moderate: We are moderately confident in the effect estimate: The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.

Low: Our confidence in the effect estimate is limited: The true effect may be substantially different from the estimate of the effect.

Very low: We have very little confidence in the effect estimate: The true effect is likely to be substantially different from the estimate of effect.

Given the complexity of epidemiological data collection and interpretation, the synthesis focused on factors that have been assessed in more than one study. Other, unique assessment results were reported in evidence tables but not further documented in the summary of findings tables for KQ1 and KQ3 to provide a concise overview. Given the relevance to the VA, all available evidence was documented for KQ2.

For KQ1 and KQ2 we took the following criteria into account to determine the level of evidence quality. These are based on an adaptation of the GRADE framework for prognostic factor research.^18^ The “phase of investigation” criterion was used as a starting point (high or moderate quality of evidence). The criteria “study limitations,” “inconsistency,” “indirectness,” “imprecision,” and “publication bias” were used to decrease the quality of evidence. The criteria “moderate / large effect size” and “exposure-response gradient” were used to increase the evidence grade where applicable.

For KQ3 we took the number of identified studies and the criteria “risk of bias,” “inconsistency,” “imprecision,” and “publication bias” into account. The starting point was high evidence because the data are based on RCTs.^17^

Publication bias was assessed with the regression test (Egger test) and the rank test (Begg test). Results indicating evidence of publication bias were reanalyzed using the trim-and-fill method to adjust for potentially missing studies.

## TECHNICAL EXPERT PANEL

The technical expert panel (TEP) for the project included Mitchell T. Wallin MD, MPH, Clinical Associate Director, VA MS Center of Excellence-East; Glenn D. Graham, MD PhD, Deputy National Director for Neurology, Specialty Care Services, VA Central Office, Christopher Bever, Jr., MD, MBA, Director of the MS Center of Excellence-East, Professor, Departments of Neurology, Pharmacology and Physical Therapy, University of Maryland School of Medicine; Jodie Haselkorn, MD, MPH, Director, MS Center of Excellence-West, Professor, Rehabilitation Medicine, VA Puget Sound Health Care System; W. Joel Culpepper, MA, PhD, Associate Director of Epidemiology and Outcomes for the MS Center of Excellence-East; John W. Rose, M.D., Chief, Division of Neuroimmunology, VA Salt Lake City Health Care System; Gary M. Franklin, MD, MPH, Research Professor, Department of Environmental and Occupational Health Sciences Medicine (Neurology) and Health Services, University of Washington; Vijayshree Yadav, MBBS, MCR, Associate Professor, Neurology, Clinical Director, MS Center, Oregon Health & Science University; John F Kurtzke MD, FACP, FAAN, Professor Emeritus of Neurology, Georgetown University, Consultant in Neurology and Neuroepidemiology, Veterans Affairs Medical Center, Washington, DC; and Aaron Turner, PhD, Mental/Behavioral Health Psychology, VA Puget Sound Health Care System.

## PEER REVIEW

A draft version of the report was reviewed by technical experts, clinical leadership, and additional peer reviewers where appropriate. Reviewer comments and how we have addressed them is documented in Appendix D.