# INTRODUCTION

Multiple sclerosis (MS) is the most common progressive disease of the central nervous system in young adults and the most common cause of serious physical disability in adults of working age.^1,2^ The estimated incidence is 7 per 100,000 per year and the median age of onset is 30 years.^3^ For the military it is a significant neurological disease burden in terms of diagnosis, management, and disability retirement.

MS is characterized pathologically by focal areas of inflammation, demyelination, gliosis, and axonal damage throughout the central nervous system.^4,5^ The course of MS is characterized by clinical relapses and disease progression. Relapse, exacerbations, or attacks, are acute, inflammatory events that occur episodically within the central nervous system. They can correspond to either the development of new focal inflammatory lesions or the reactivation of old lesions, and after an exacerbation, symptoms spontaneously remit, either partially or completely. Progression describes a steady deterioration in neurologic function associated with new symptoms and continuously worsening disability which takes place over a period of at least 6 (Poser criteria) or 12 months (McDonald criteria).^6,7^ Once progression has developed, the course is continuous despite occasional plateaus and temporary minor improvements.^8^

MS disease presentation is very heterogeneous with variable clinical manifestations that evolve over time. About 80% of patients present with relapsing-remitting disease which manifests in relapses followed by periods of partial or complete recovery (remissions). Other subtypes of MS include secondary progressive MS (patients develop relapsing-remitting MS but then begin progressing with or without relapses). In about 50% of patients the course of MS changes from relapsing-remitting to secondary progressive disease after 10 years.^9^ Active progressive MS shows a slow progression of disability from onset with periods of stability and occasional relapses, while patients with primary progressive MS show progressive worsening in disability from onset without exacerbations. It is estimated that while 15% of patients with MS will become severely disabled within a short time, for 25% of patients MS will never affect daily life.^10^

Epidemiologic data show that rates of MS appear to vary with environmental factors. ^10^ This suggests a role of potentially modifiable risk factors associated with the onset and phenotypic manifestation of the disease. Similarly, the course of MS varies with demographic variables and possibly other factors. Furthermore, the mechanism that changes the disease pattern from relapsing-remitting to secondary progressive MS is largely unknown.^9^ Factors that may explain the diversity in clinical presentation, help predict the course of the disease, and identify potential triggers of disease progression are of great interest to patients and clinicians, in particular modifiable risk factors.^11^

Disease-modifying therapies for relapsing forms of MS are only partially effective in slowing short-term morbidity and there are no effective medication options for progressive MS.^12^ Additional MS treatment and management options are needed to support patients with a diagnosis of MS. Some risk factors associated with the onset or progression of MS may be translatable into interventions, such as in the case of the potential risk factor vitamin D deficiency, which can be tested in effectiveness trials by treating MS patients with a vitamin D supplement.^13^

This project focuses on empirical evidence on modifiable exposures and risk factors that are related to MS progression and approaches to reduce progression that are directed at modifiable risk factors. This review will be used by the VA Multiple Sclerosis Centers of Excellence to initiate new research studies, refine clinical guidelines, and plan for targeted disease-modifying and disease-prevention strategies.