# APPENDIX D PEER REVIEW COMMENTS/AUTHOR RESPONSES

Comment | Response
Studies missing - Yes - Studies evaluating geography itself as a risk factor, studies prior to 1973, studies involving co-morbidity | The identified studies on associations between geography and progression are shown in the “other” and the “multiple” risk factor section. Studies published prior to 1973 were eligible for inclusion in the review and all databases were searched without date restriction. We have added the eligibility criteria after the description of the included studies in the result section to avoid ambiguity. In addition, we have emphasized that databases were searched from inception. Co-morbidities were outside the scope of this review but we have expanded the future research section to indicate that sufficient literature exists for systematic reviews on several individual comorbidities.
It would have been useful to add obesity related studies in the review as it appears to be an important co-morbid condition and related information would have been of great research as well as clinical significance. | See above. In particular there is a growing literature on weight and MS progression; we have expanded on this issue in the future research section.
Several typographical errors are present in the draft, that I assume will be reviewed carefully towards the final draft. | Typographical errors will be correct before publication
Pg 1/Line 8: Traumatic brain injury is more common than MS in younger adults but is not progressive. I'd reword this sentence as follows: Multiple sclerosis (MS) is the most common progressive disease of the central nervous system in young adults and the cause of serious physical disability in adults of working age. | Revised as suggested
Pg 1/Line 21: Use “MS” throughout the manuscript after it's defined. | We have revised the text accordingly but left the key questions as is to avoid ambiguity
Pg 1/Line 49: Is this a preliminary report vs. final? | The draft report is subjected to peer review
Pg 3/Line 16: “Concurrent” is not commonly used and is confusing. It should be replaced with retrospective. | To address this point, we have added a definition to avoid confusion (measuring the exposure status and the outcome at the same time point, eg, current alcohol intake)
Pg 5/Line 5: Change “Out” to Our. | Changed
Pg 5/Line 25: There are several redundant and inaccurate statements in the conclusion. The association between MS progression and vitamin D supplementation is not significant but the conclusions imply it is related. The conclusion should be modified to something like the following: Our systematic review documents the available evidence on modifiable risk factors for MS progression. Associations with MS progression are strongest for smoking. None of the intervention studies examining exercise, dietary, and vitamin D supplementation reported a statistically significant effect on MS disability. Other than smoking cessation, there are no other modifiable risk factors that can be given support from this review as an intervention worthy of slowing MS progression. | To address the perceived redundancy we have divided the conclusions into multiple paragraphs: one characterizes the overall evidence base, one summarizes the risk factor studies, one summarizes the intervention RCTs, and the last one describes the evidence for factors that were addressed in both, risk factor and in intervention studies. The correlation between EDSS scores and vitamin D level was statistically significant. We have revised the sentence to avoid the perceived inaccuracy.
Pg 8/Line 3: There are several reviews of MS risk factors published in the literature. Some are comprehensive in scope. The statement below is confusing in implying there are multiple reviews of risk factors translated into treatment options. Is this referring to dietary or exercise treatments? There is an emerging body of research that evaluates risk factors translated into treatment options but no systematic review has to date comprehensively synthesized the available evidence. | We have deleted the sentence
Pg 18/Line 8: Why was 1973 used as the starting year (vs. 1970)? | See above
Pg 51/Line 5: There is no figure in the box. | Unfortunately the conversion to PDF in the online editorial manager system did not display the figure; this will be corrected in the final report.
Forest plots: There is no confidence interval represented on the summary measure of risk in the diagram. This should be included. | We were not sure how this perception came about, confidence intervals are shown for individual studies and the pooled effect in all forest plots
Please see editorial suggestions and comments in the uploaded document. | Thank you for your careful review; we have accepted all editorial changes
p. 10: So if I understand correctly, a study on solely Relapsing Remitting MS (RR MS), the most common disease type, would have been excluded - even though patients with RR MS often progress over time? | We have revised the sentence to avoid confusion
p. 24: Sentence is unclear. Which of the studies does this phrase refer to? | Author name added to avoid ambiguity
p. 50: awkward wording | Revised to clarify that the individually assessed risk factors as well as predicted outcomes were very specific
p. 51: Figure missing from draft | See above
p. 51: I assume you mean since the Vit D values were dichotomized, rather than reported as a continuous variable? The statement is unclear as written, since the study did in fact use the EDSS. | The studies did not report on a correlation, hence they could not be added to the meta-analysis; we have clarified this in the text
p. 52: Graphs have a diagonal line, which should be deleted. | Formatting changes are due to converting to PDF and will be corrected in the final report
p. 54: Which - any alcohol consumption, or heavy drinking, or both? | Clarified
p. 56: Explain the “downgrades” (or refer to the text in the legend) | Added
p. 69: Unclear in this context | We have added more explanation regarding the waitlist condition
p. 78: Would this be better expressed as “pregnancy” rather than “children“? | See above
p. 82: Unclear. Do you mean “for which the published evidence demonstrates their amenability…”. Need a clear statement to conclude the review! | We have revised the draft conclusions
Did any study examine the impact of moving to a different region/climate/latitude during childhood or early adulthood? | We did not identify such a study
I have a general concern that there may be confusion in discussion of studies between change from Relapsing-Remitting MS (RR MS) to Secondary Progressive MS (SP MS), and progression of disability caused by MS, which can occur both in RR MS and SP MS. | Yes, several studies did not restrict to RR MS and studies used a variety of outcome measures. To address this concern, we have highlighted those studies in the summary of findings section that specifically reported on the change from RR to SP MS and those that only included patients with RR MS at baseline
Was the post-partum period also analyzed separate from pregnancy itself? It is commonly held that MS is likely to be quiescent during pregnancy, but the risk for relapses or progression is increased from baseline during the immediate post-partum interval. | Given the complexity of the topic and the diversity across the large number of studies that should be addressed in a separate systematic review we have added this topic to the list of suggested future research studies.
Page 5, line 5: Change “Out” to “Our” | See above
Page 7, line 16: Change “described” to “characterized pathologically” and add “focal areas of” before “inflammation…” | Changed as suggested
Page 7, lines 35 to 37: Change “Progressive relapsing MS” to “Active progressive MS” The classification system for MS subtypes was revised in 2014 to remove the classification of “progressive relapsing” and replace it with the classification of “active progressive” This is given in Reference 8. | Changed as suggested
Page 10, line 60: Azathioprine is listed as a medication specifically designed for MS, which . Azathioprine was originally developed as an antineoplastic agent it is now used for immunosuppression in autoimmune diseases and organ transplantation. Other drugs in this class that were omitted from the list include methotrexate and cyclophosphamide. Cladribine, listed later, probably belongs in the same list. | We have removed the specific examples and reduced the text to one example per medication type to address this point
Page 13, line 54: Move “presented” to after “statistics” | We have revised the sentence
Page 15, line 14: After “East” add “, Professor, Departments of Neurology, Pharmacology and Physical Therapy, University of Maryland School of Medicine” | Added
Page 15, line 14: After “MPH” add “, Director, MS Center of Excellence - West” | Added
Page 15, line 26: Change,“PHD” to “PhD” | Changed
Tables 1 to 7: I may not be reading the tables correctly but I did not see a column indicating the rating of the quality of the evidence in each study. I believe that Appendix C deals with that issue in detail but should some summary indication be included on these tables? | The studies were assessed with a number of individual risk of bias criteria which exceeded the available space in the evidence tables. To address this point we have systematically added information on the risk of bias to the result sections following the evidence tables
Tables 1 to 7, case definition: I may not be understanding what is being reported here. I am used to this column being used to report whether an acceptable case definition was used by the study in question. In most cases this would involve a diagnosis of MS based on published criteria such as the Poser, McDonald or modified McDonald criteria. Cases might be further restricted based on disability range using a scale like the EDSS score. The entries in this column don't seem to fit this so I am unclear on what is being displayed here. I am also not clear on whether publications were reviewed to ensure that accepted case definitions were used. | We have revised the term to “predicted variable” to avoid confusion with MS diagnostic criteria. In addition, we have added the diagnostic criteria for prospective studies to the evidence tables.