# APPENDIX C CRITERIA USED IN QUALITY ASSESSMENT

This appendix documents the individual risk of bias criteria used to assess included studies. In addition, it documents the criteria used to rate the quality of evidence across studies.

## RISK OF BIAS ASSESSMENT OF KQ1 AND KQ2 STUDIES

A large number of diverse studies contributed to the review. We broadly categorized risk factor studies into concurrent, retrospective, and prospective studies. Concurrent and retrospective studies can provide only limited information on questions of progression, regardless of their methodological quality, and these studies were not further differentiated.

The identified prospective studies relevant to KQ1 and KQ2 were assessed with QUIPS (QUality In Prognosis Studies), a critical appraisal tool for prognostic studies. QUIPS assesses the domains study participation, study attrition, prognostic factor measurement, outcome measurement, study confounding, and statistical analysis and reporting.^15^ For each domain we determined whether the study indicates high risk of bias, moderate risk of bias, or low risk of bias.

Appendix Table 1 Risk of Bias: KQ1 and KQ2 Prospective Studies

Author, year | Study Participation | Study Attrition | Prognostic Factor Measurement | Outcome Measurement | Study Confounding | Statistical Analysis and Reporting | KQ1 and KQ2
Ascherio, 2014^20^ | High | Moderate | Low | Low | Moderate | Low
Confavreux, 1998^30^ | Low | Low | Low | Low | High | Low
Detels, 1982^35^ | Low | Moderate | Moderate | High | Moderate | Moderate
Mowry, 2012^69^ | Low | Low | Low | Low | Low | Low
Pasto, 2012^72^ | Low | Low | Low | Low | High | Low
Pittas, 2009^76^ | Moderate | Low | Low | Low | Low | Low
Runmarker, 1995^113^ | Moderate | Low | Low | Low | High | Moderate
Shammas, 2014^87^ | High | Low | Low | Low | Moderate | High
Soilu-Hanninen, 2007^91^ | High | Low | Low | Low | Moderate | High
Stuifbergen, 2006^96^ | Low | Low | Low | Low | Low | Low
Sundstom, 2008^97^ | Moderate | Low | Moderate | Low | Low | Moderate
Swank, 1990^98^ | Low | Low | High | Low | Low | Moderate
Tepavcevic, 2010^112^ | Moderate | Moderate | High | Low | Moderate | High

Legend:

Study participation: Prompting items: a. Adequate participation in the study by eligible persons, b. Description of the source population or population of interest, c. Description of the baseline study sample, d. Adequate description of the sampling frame, and recruitment, e. Adequate description of the period and place of recruitment, f. Adequate description of inclusion and exclusion criteria. Ratings: High risk: The relationship between the PF and outcome is very likely to be different for participants and eligible nonparticipants; Moderate bias: The relationship between the PF and outcome may be different for participants and eligible nonparticipants; Low bias: The relationship between the PF and outcome is unlikely to be different for participants and eligible nonparticipants

Study attrition: a. Adequate response rate for study participants, b. Description of attempts to collect information on participants who dropped out, c. Reasons for loss to follow-up are provided, d. Adequate description of participants lost to follow-up, e. There are no important differences between participants who completed the study and those who did not. Ratings: High bias: The relationship between the PF and outcome is very likely to be different for completing and non-completing participants; Moderate bias: The relationship between the PF and outcome may be different for completing and non-completing participants; Low bias: The relationship between the PF and outcome is unlikely to be different for completing and non-completing participants

Prognostic Factor Measurement: Prompting items: a. A clear definition or description of the PF is provided, b. Method of PF measurement is adequately valid and reliable, c. Continuous variables are reported or appropriate cut points are used, d. The method and setting of measurement of PF is the same for all study participants, e. Adequate proportion of the study sample has complete data for the PF, f. Appropriate methods of imputation are used for missing PF data. Ratings: High bias: The measurement of the PF is very likely to be different for different levels of the outcome of interest, Moderate bias: The measurement of the PF may be different for different levels of the outcome of interest, Low bias: The measurement of the PF is unlikely to be different for different levels of the outcome of interest

Outcome Measurement: Prompting items: a. clear definition of the outcome is provided, b. Method of outcome measurement used is adequately valid and reliable, c. The method and setting of outcome measurement is the same for all study participants. Ratings: High bias: The measurement of the outcome is very likely to be different related to the baseline level of the PF, Moderate bias: The measurement of the outcome may be different related to the baseline level of the PF, Low bias: The measurement of the outcome is unlikely to be different related to the baseline level of the PF

Study Confounding: Prompting items: a. All important confounders are measured, b. Clear definitions of the important confounders measured are provided, c. Measurement of all important confounders is adequately valid and reliable, d. The method and setting of confounding measurement are the same for all study participants, e. Appropriate methods are used if imputation is used for missing confounder data, f. Important potential confounders are accounted for in the study design, g. Important potential confounders are accounted for in the analysis. Ratings: High bias: The observed effect of the PF on the outcome is very likely to be distorted by another factor related to PF and outcome, Moderate bias: The observed effect of the PF on outcome may be distorted by another factor related to PF and outcome, Low bias: The observed effect of the PF on outcome is unlikely to be distorted by another factor related to PF and outcome

Statistical Analysis and Reporting: Prompting items: a. Sufficient presentation of data to assess the adequacy of the analytic strategy, b. Strategy for model building is appropriate and is based on a conceptual framework or model, c. The selected statistical model is adequate for the design of the study, d. There is no selective reporting of results. Ratings: High bias: The reported results are very likely to be spurious or biased related to analysis or reporting, Moderate bias: The reported results may be spurious or biased related to analysis or reporting, Low bias: The reported results are unlikely to be spurious or biased related to analysis or reporting

## RISK OF BIAS ASSESSMENT OF KQ3 STUDIES

Studies relevant to KQ3 were assessed with the Cochrane risk of bias tool. The tool assesses random sequence generation (selection bias), allocation concealment (selection bias), blinding of participants and providers (performance bias), blinding of outcome assessors (detection bias), completeness of reporting outcome data (attrition bias), selective outcome reporting (reporting bias), and other sources of bias (if appropriate) for each of the included studies. For each domain we determined whether the study indicates a high risk of bias, a low risk of bias, or an unclear risk of bias.

Appendix Table 2 Risk of Bias: KQ3 Studies

Author, year | Random sequence generation | Allocation concealment | Blinding of participants/providers | Blinding of outcome assessors | Incomplete outcome data | Selective reporting | Other bias
Armutlu, 2001^19^ | Unclear | Unclear | High risk | Low risk | Low risk | Low risk | Low risk
Bates, 1977^24^ | Unclear | Unclear | Low risk | Low risk | Low risk | High risk | Low risk
Bates, 1978^25^ | Unclear | Unclear | Low risk | Low risk | Unclear | Unclear | Unclear
Bates, 1989^23^ | Unclear | Unclear | Low risk | Low risk | Unclear | Unclear | Unclear
Bjarnadottir, 2007^26^ | Unclear | Low risk | High risk | High risk | Unclear | Unclear | High risk
Burton, 2010^28^ | Low risk | Low risk | Low risk | Low risk | High risk | Low risk | Low risk
Carter, 2013^29^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Low risk
Conklyn, 2010^31^ | Unclear | Unclear | High risk | High risk | Low risk | Low risk | High risk
Dalgas, 2009^32^ | Unclear | Low risk | High risk | Low risk | Low risk | Low risk | Low risk
DeBolt, 2004^34^ | Unclear | Unclear | High risk | High risk | Unclear | Unclear | Unclear
Fimland, 2010^37^ | Unclear | Unclear | Unclear | Unclear | Low risk | Low risk | High risk
Golzari, 2010^42^ | Unclear | Unclear | High risk | Low risk | Unclear | Unclear | High risk
Harbige, 2007^44^ | Unclear | Unclear | Low risk | Low risk | Unclear | Unclear | High risk
Kampman, 2012^49^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk
Lo, 2008^56^ | Unclear | Unclear | High risk | Low risk | Low risk | Low risk | High risk
Millar, 1973^65^ | Low risk | Low risk | Low risk | Low risk | High risk | Low risk | Low risk
Miller, 2011^66^ | Unclear | Unclear | High risk | Unclear | Low risk | Low risk | Unclear
Mosayebi, 2011^67^ | Unclear | Low risk | Low risk | Low risk | High risk | Low risk | Unclear
Pantzaris, 2013^71^ | Low risk | Low risk | Low risk | Low risk | Low risk | Unclear | Unclear
Paty, 1978^73^ | Unclear | Unclear | Low risk | Low risk | High risk | Unclear | Unclear
Petajan, 1996^74^ | Unclear | Unclear | High risk | Low risk | High risk | Low risk | High risk
Pfalzer, 2011^75^ | Unclear | Unclear | High risk | Unclear | Unclear | Low risk | Low risk
Ramirez-Ramirez, 2013^78^ | Low risk | Low risk | Low risk | Low risk | High risk | Low risk | Low risk
Rampello, 2007^79^ | Low risk | Low risk | Unclear | Unclear | High risk | Unclear | Unclear
Rezapour-Firouzi, 2013^80^ | Low risk | Low risk | Low risk | Low risk | High risk | Low risk | High risk
Romberg, 2004^81^ | Unclear | Unclear | High risk | High risk | Low risk | Unclear | Unclear
Sangelaji, 2014^83^ | Unclear | Low risk | High risk | Unclear | High risk | Low risk | Low risk
Schwartz, 2012^84^ | Low risk | Low risk | High risk | Low risk | High risk | Low risk | High risk
Shaygannejad, 2012^88^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk
Soilu-Hanninen, 2012^128^ | Low risk | Low risk | Low risk | Low risk | High risk | Unclear | High risk
Solari, 1999^92^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Low risk
Stein, 2011^94^ | Low risk | Low risk | High risk | Low risk | Low risk | High risk | High risk
Torkildsen, 2012^101^ | Low risk | Low risk | Low risk | Low risk | Unclear | Low risk | Unclear
Weinstock-Guttman, 2005^107^ | Unclear | Unclear | Low risk | Low risk | High risk | Low risk | High risk
Wiles, 2001^109^ | Unclear | Unclear | High risk | Low risk | Low risk | Low risk | Low risk
Yadav, 2014^110^ | Unclear | Unclear | High risk | Low risk | High risk | Low risk | High risk

Legend:

Random sequence generation: Low risk: The investigators describe a random component in the sequence generation process such as: Referring to a random number table, Using a computer random number generator; Coin tossing; Shuffling cards or envelopes; Throwing dice; Drawing of lots; Minimization; High risk: The investigators describe a non-random component in the sequence generation process. Usually, the description would involve some systematic, non-random approach, for example: Sequence generated by odd or even date of birth; Sequence generated by some rule based on date (or day) of admission; Sequence generated by some rule based on hospital or clinic record number; Allocation by judgment of the clinician; Allocation by preference of the participant; Allocation based on the results of a laboratory test or a series of tests; Allocation by availability of the intervention. Unclear: Insufficient information about the sequence generation process to permit judgment of ‘Low risk’ or ‘High risk’.

Allocation concealment: Low risk: Participants and investigators enrolling participants could not foresee assignment because one of the following, or an equivalent method, was used to conceal allocation: Central allocation (including telephone, web-based and pharmacy-controlled randomization); Sequentially numbered drug containers of identical appearance; Sequentially numbered, opaque, sealed envelopes. High risk: Participants or investigators enrolling participants could possibly foresee assignments and thus introduce selection bias, such as allocation based on: Using an open random allocation schedule (eg, a list of random numbers); Assignment envelopes were used without appropriate safeguards (eg, if envelopes were unsealed or non-opaque or not sequentially numbered); Alternation or rotation; Date of birth; Case record number; Any other explicitly unconcealed procedure. Unclear: Insufficient information to permit judgment of ‘Low risk’ or ‘High risk’. This is usually the case if the method of concealment is not described or not described in sufficient detail to allow a definite judgment – for example if the use of assignment envelopes is described, but it remains unclear whether envelopes were sequentially numbered, opaque and sealed.

Blinding of participants and personnel: Low risk: No blinding or incomplete blinding, but the review authors judge that the outcome is not likely to be influenced by lack of blinding; Blinding of participants and key study personnel ensured, and unlikely that the blinding could have been broken. High risk: No blinding or incomplete blinding, and the outcome is likely to be influenced by lack of blinding; Blinding of key study participants and personnel attempted, but likely that the blinding could have been broken, and the outcome is likely to be influenced by lack of blinding. Unclear: Insufficient information to permit judgment of ‘Low risk’ or ‘High risk’; The study did not address this outcome.

Blinding of outcome assessment: Low risk: No blinding of outcome assessment, but the review authors judge that the outcome measurement is not likely to be influenced by lack of blinding; Blinding of outcome assessment ensured, and unlikely that the blinding could have been broken. High risk: No blinding of outcome assessment, and the outcome measurement is likely to be influenced by lack of blinding; Blinding of outcome assessment, but likely that the blinding could have been broken, and the outcome measurement is likely to be influenced by lack of blinding. Unclear: Insufficient information to permit judgment of ‘Low risk’ or ‘High risk’; The study did not address this outcome.

Incomplete outcome data: Low risk: No missing outcome data; Reasons for missing outcome data unlikely to be related to true outcome (for survival data, censoring unlikely to be introducing bias); Missing outcome data balanced in numbers across intervention groups, with similar reasons for missing data across groups; For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk not enough to have a clinically relevant impact on the intervention effect estimate; For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes not enough to have a clinically relevant impact on observed effect size; Missing data have been imputed using appropriate methods. High risk: Reason for missing outcome data likely to be related to true outcome, with either imbalance in numbers or reasons for missing data across intervention groups; For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk enough to induce clinically relevant bias in intervention effect estimate; For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes enough to induce clinically relevant bias in observed effect size; ‘As-treated’ analysis done with substantial departure of the intervention received from that assigned at randomization; Potentially inappropriate application of simple imputation. Unclear: Insufficient reporting of attrition/exclusions to permit judgment of ‘Low risk’ or ‘High risk’ (eg, number randomized not stated, no reasons for missing data provided); The study did not address this outcome.

Selective reporting: Low risk: The study protocol is available and all of the study's pre-specified (primary and secondary) outcomes that are of interest in the review have been reported in the pre-specified way; The study protocol is not available but it is clear that the published reports include all expected outcomes, including those that were pre-specified (convincing text of this nature may be uncommon). High risk: Not all of the study's pre-specified primary outcomes have been reported; One or more primary outcomes is reported using measurements, analysis methods or subsets of the data (eg, subscales) that were not pre-specified; One or more reported primary outcomes were not pre-specified (unless clear justification for their reporting is provided, such as an unexpected adverse effect); One or more outcomes of interest in the review are reported incompletely so that they cannot be entered in a meta-analysis; The study report fails to include results for a key outcome that would be expected to have been reported for such a study. Unclear: Insufficient information to permit judgment of ‘Low risk’ or ‘High risk’. It is likely that the majority of studies will fall into this category.

Other bias: Low risk: The study appears to be free of other sources of bias. High risk: There is at least one important risk of bias. For example the study had a potential source of bias related to the specific study design used; has been claimed to have been fraudulent; or had some other problem. Unclear: There may be a risk of bias, but there is either: Insufficient information to assess whether an important risk of bias exists; or insufficient rationale or evidence that an identified problem will introduce bias.

## CRITERIA TO RATE THE BODY OF EVIDENCE FOR KQ1 AND KQ2

The GRADE framework for prognostic factor research^18^ differentiates 8 criteria that are used to evaluate the quality of the evidence across all identified studies:

The phase of investigation differentiates whether the risk factor evidence is primarily based on a study that aimed to identify potential prognostic factors (moderate quality) rather than based on studies aiming to confirm identified associations or explanatory research aiming to understand prognostic pathways (high quality).

Study limitations took the assessment frame into account by differentiating whether the risk factor status and the outcome variable were assessed at the same time (concurrently), retrospectively, or prospectively. Prospective studies were further differentiated by the risk of bias based on the QUIPS scores.

Inconsistency assessed whether the identified association was consistently present across studies and across study designs (eg, present in concurrent and prospective studies).

Indirectness took into account whether the available research studies does not accurately reflect the review question. Examples are cases where the only available research studies reported on vitamin D status, rather than a directly patient-modifiable risk factor such as vitamin D intake.

Evidence was downgraded for imprecision if the sample size was insufficient, the confidence interval was wide and overlapped the value of no effect, there were less than 10 outcome events for each prognostic variable, or there were less than 100 cases reaching endpoints.

Evidence was downgraded for publication bias unless the value of the risk or protective factor in predicting the outcome has been repetitively investigated.

Evidence for individual risk factors may be upgraded if effects are moderate or large or there is evidence of exposure-gradient response for factors measured at different doses.

## CRITERIA TO RATE THE BODY OF EVIDENCE FOR KQ3

For KQ3 we took the criteria risk of bias, inconsistency, indirectness, imprecision, publication bias, large effect, dose response, and all plausible residual confounding would reduce a demonstrated effect and/or would suggest a spurious effect if no effect was observed into account. The starting point was high evidence because the data are based on RCTs.

Risk of bias, inconsistency, indirectness, imprecision, and publication bias can lower the quality. Large effect, dose response, and all plausible residual confounding can upgrade the quality of the body of evidence. ^17^

Risk of bias evaluations were based on the above documented Cochrane Risk of Bias tool assessments. Inconsistency took the direction and the size of effects across studies into account. Indirectness may assess whether comparative effects are based on head-to-head trial evidence or was obtained from meta-regressions and subgroup analyses. Imprecision takes the confidence interval around the point estimate into account. Publication bias was assessed to determine whether there is evidence that pertinent studies, in this case negative effect studies are missing.