# APPENDIX B STUDY SELECTION AND LIST OF EXCLUDED STUDIES

The search yield, title and abstract screening results; full text decisions, and the data extraction are documented in electronic databases which can be obtained from the authors, in compliance with standard data sharing requirements.

This appendix lists the citation of publications obtained as full text but not meeting inclusion criteria together with the reason for excluding the publication.

## EXCLUDE: OUTCOME

Excluded publications not reporting on MS progression:

1 Acheson ED, Bachrach CA. (1960). The distribution of multiple sclerosis in U. S. veterans by birthplace. American Journal of Hygiene.
2 Ackerman KD, Stover A, Heyman R, et al. (2003). Relationship of cardiovascular reactivity, stressful life events, and multiple sclerosis disease activity. Brain Behav Immun.
3 Amato MP, Ponziani G, Rossi F, Liedl CL, Stefanile C, Rossi L. (2001). Quality of life in multiple sclerosis: the impact of depression, fatigue and disability. Multiple Sclerosis (Houndmills, Basingstoke, England).
4 Ayatollahi P, Nafissi S, Eshraghian MR, Kaviani H, Tarazi A. (2007). Impact of depression and disability on quality of life in Iranian patients with multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
5 Bansi J, Bloch W, Gamper U, Kesselring J. (2013). Training in MS: influence of two different endurance training protocols (aquatic versus overland) on cytokine and neurotrophin concentrations during three week randomized controlled trial. Multiple Sclerosis (Houndmills, Basingstoke, England).
6 Barth SK, Kang HK, Bullman TA, Wallin MT. (2009). Neurological mortality among U.S. veterans of the Persian Gulf War: 13-year follow-up. American Journal of Industrial Medicine.
7 Basak T, Unver V, Demirkaya S. (2014). Activities of Daily Living and Self-Care Agency in Patients with Multiple Sclerosis for the First 10 Years. Rehabilitation Nursing: The Official Journal of the Association of Rehabilitation Nurses.
8 Baumstarck K, Pelletier J, Boucekine M, Auquier P. (2015). Predictors of quality of life in patients with relapsing-remitting multiple sclerosis: A 2-year longitudinal study. Rev Neurol (Paris).
9 Bayraktar D, Guclu-Gunduz A, Yazici G, et al. (2013). Effects of Ai-Chi on balance, functional mobility, strength and fatigue in patients with multiple sclerosis: a pilot study. NeuroRehabilitation.
10 Bee YS, Lin MC, Wang CC, Sheu SJ. (2003). Optic neuritis: clinical analysis of 27 cases. The Kaohsiung Journal of Medical Sciences.
11 Beebe GW, Kurtzke JF. (1969). Herpes zoster and multiple sclerosis. British Medical Journal.
12 Beebe GW, Kurtzke JF, Kurland LT, Auth TL, Nagler B. (1967). Studies on the natural history of multiple sclerosis. 3. Epidemiologic analysis of the army experience in World War II. Neurology.
13 Beer S, Aschbacher B, Manoglou D, Gamper E, Kool J, Kesselring J. (2008). Robot-assisted gait training in multiple sclerosis: a pilot randomized trial. Multiple Sclerosis (Houndmills, Basingstoke, England).
14 Beier M, D'Orio V, Spat J, Shuman M, Foley FW. (2014). Alcohol and substance use in multiple sclerosis. Journal of the Neurological Sciences.
15 Bobowick AR, Kurtzke JF, Brody JA, Hrubec Z, Gillespie M. (1978). Twin study of multiple sclerosis: an epidemiologic inquiry. Neurology.
16 Bombardier CH, Cunniffe M, Wadhwani R, Gibbons LE, Blake KD, Kraft GH. (2008). The efficacy of telephone counseling for health promotion in people with multiple sclerosis: a randomized controlled trial. Archives of Physical Medicine and Rehabilitation.
17 Bombardier CH, Ehde DM, Gibbons LE, et al. (2013). Telephone-based physical activity counseling for major depression in people with multiple sclerosis. Journal of Consulting and Clinical Psychology.
18 Briken S, Gold SM, Patra S, et al. (2014). Effects of exercise on fitness and cognition in progressive MS: a randomized, controlled pilot trial. Multiple Sclerosis (Houndmills, Basingstoke, England).
19 Broekmans T, Roelants M, Alders G, Feys P, Thijs H, Eijnde BO. (2010). Exploring the effects of a 20-week whole-body vibration training programme on leg muscle performance and function in persons with multiple sclerosis. J Rehabil Med.
20 Broekmans T, Roelants M, Feys P, et al. (2011). Effects of long-term resistance training and simultaneous electro-stimulation on muscle strength and functional mobility in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
21 Brown JS. (2003). Correlation of mollicutes and their viruses with multiple sclerosis and other demyelinating diseases. Medical Hypotheses.
22 Buljevac D, Hop WC, Reedeker W, et al. (2003). Self reported stressful life events and exacerbations in multiple sclerosis: prospective study. BMJ.
23 Burschka JM, Keune PM, Oy UH, Oschmann P, Kuhn P. (2014). Mindfulness-based interventions in multiple sclerosis: beneficial effects of Tai Chi on balance, coordination, fatigue and depression. BMC Neurol.
24 Cakt BD, Nacir B, Genc H, et al. (2010). Cycling progressive resistance training for people with multiple sclerosis: a randomized controlled study. American Journal of Physical Medicine & Rehabilitation / Association of Academic Physiatrists.
25 Carter A, Daley A, Humphreys L, et al. (2014). Pragmatic intervention for increasing self-directed exercise behaviour and improving important health outcomes in people with multiple sclerosis: a randomised controlled trial. Multiple Sclerosis (Houndmills, Basingstoke, England).
26 Carvalho AT, Veiga A, Morgado J, et al. (2014). Multiple sclerosis and motherhood choice: an observational study in Portuguese women patients. Revista de Neurologia.
27 Castro-Sanchez AM, Mataran-Penarrocha GA, Lara-Palomo I, Saavedra-Hernandez M, Arroyo-Morales M, Moreno-Lorenzo C. (2012). Hydrotherapy for the treatment of pain in people with multiple sclerosis: a randomized controlled trial. Evidence-based Complementary and Alternative Medicine: eCAM.
28 Cattaneo D, Jonsdottir J, Zocchi M, Regola A. (2007). Effects of balance exercises on people with multiple sclerosis: a pilot study. Clin Rehabil.
29 Chataway J, Schuerer N, Alsanousi A, et al. (2014). Effect of high-dose simvastatin on brain atrophy and disability in secondary progressive multiple sclerosis (MS-STAT): a randomised, placebo-controlled, phase 2 trial. Lancet.
30 Chruzander C, Johansson S, Gottberg K, et al. (2013). A 10-year follow-up of a population-based study of people with multiple sclerosis in Stockholm, Sweden: changes in disability and the value of different factors in predicting disability and mortality. Journal of the Neurological Sciences.
31 Cioncoloni D, Innocenti I, Bartalini S, et al. (2014). Individual factors enhance poor health-related quality of life outcome in multiple sclerosis patients. Significance of predictive determinants. Journal of the Neurological Sciences.
32 Claerbout M, Gebara B, Ilsbroukx S, et al. (2012). Effects of 3 weeks' whole body vibration training on muscle strength and functional mobility in hospitalized persons with multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
33 Collett J, Dawes H, Meaney A, et al. (2011). Exercise for multiple sclerosis: a single-blind randomized trial comparing three exercise intensities. Multiple Sclerosis (Houndmills, Basingstoke, England).
34 Coote S, Hughes L, Rainsford G, Minogue C, Donnelly A. (2015). Pilot randomized trial of progressive resistance exercise augmented by neuromuscular electrical stimulation for people with multiple sclerosis who use walking AIDS. Archives of Physical Medicine and Rehabilitation.
35 Dalgas U, Stenager E, Jakobsen J, et al. (2010). Fatigue, mood and quality of life improve in MS patients after progressive resistance training. Multiple Sclerosis (Houndmills, Basingstoke, England).
36 Dettmers C, Sulzmann M, Ruchay-Plossl A, Gutler R, Vieten M. (2009). Endurance exercise improves walking distance in MS patients with fatigue. Acta Neurologica Scandinavica.
37 D'Hooghe M B, Feys P, Deltour S, et al. (2014). Impact of a 5-day expedition to machu picchu on persons with multiple sclerosis. Multiple Sclerosis International.
38 Dlugonski D, Motl RW, Mohr DC, Sandroff BM. (2012). Internet-delivered behavioral intervention to increase physical activity in persons with multiple sclerosis: sustainability and secondary outcomes. Psychology, Health & Medicine.
39 Dodd KJ, Taylor NF, Shields N, Prasad D, McDonald E, Gillon A. (2011). Progressive resistance training did not improve walking but can improve muscle performance, quality of life and fatigue in adults with multiple sclerosis: a randomized controlled trial. Multiple Sclerosis (Houndmills, Basingstoke, England).
40 Eftekhari E, Mostahfezian M, Etemadifar M, Zafari A. (2012). Resistance training and vibration improve muscle strength and functional capacity in female patients with multiple sclerosis. Asian Journal of Sports Medicine.
41 Ennis M, Thain J, Boggild M, Baker GA, Young CA. (2006). A randomized controlled trial of a health promotion education programme for people with multiple sclerosis. Clin Rehabil.
42 Fernandez-Jimenez E, Arnett PA. (2014). Impact of neurological impairment, depression, cognitive function and coping on quality of life of people with multiple sclerosis: A relative importance analysis. Multiple Sclerosis (Houndmills, Basingstoke, England).
43 Fryze W, Mirowska-Guzel D, Wiszniewska M, Darda-Ledzion L, Czlonkowska A, Czlonkowska A. (2006). Alternative methods of treatment used by multiple sclerosis patients in Poland. Neurologia i Neurochirurgia Polska.
44 Garrett M, Hogan N, Larkin A, Saunders J, Jakeman P, Coote S. (2013). Exercise in the community for people with multiple sclerosis - a follow-up of people with minimal gait impairment. Mult Scler J.
45 Glad SB, Aarseth JH, Nyland H, Riise T, Myhr KM. (2010). Benign multiple sclerosis: a need for a consensus. Acta Neurologica Scandinavica Supplementum.
46 Golan D, Somer E, Dishon S, Cuzin-Disegni L, Miller A. (2008). Impact of exposure to war stress on exacerbations of multiple sclerosis. Annals of Neurology.
47 Golan D, Staun-Ram E, Glass-Marmor L, et al. (2013). The influence of vitamin D supplementation on melatonin status in patients with multiple sclerosis. Brain Behav Immun.
48 Harrison T, Stuifbergen A, Adachi E, Becker H. (2004). Marriage, impairment, and acceptance in persons with multiple sclerosis. Western Journal of Nursing Research.
49 Hart S, Fonareva I, Merluzzi N, Mohr DC. (2005). Treatment for depression and its relationship to improvement in quality of life and psychological well-being in multiple sclerosis patients. Quality of Life Research: An International Journal of Quality of Life Aspects of Treatment, Care and Rehabilitation.
50 Hayes HA, Gappmaier E, LaStayo PC. (2011). Effects of high-intensity resistance training on strength, mobility, balance, and fatigue in individuals with multiple sclerosis: a randomized controlled trial. Journal of Neurologic Physical Therapy: JNPT.
51 Hellwig K, Haghikia A, Rockhoff M, Gold R. (2012). Multiple sclerosis and pregnancy: experience from a nationwide database in Germany. Ther Adv Neurol Disord.
52 Helmick CG, Wrigley JM, Zack MM, et al. (1989). Multiple sclerosis in Key West, Florida. American Journal of Epidemiology.
53 Hilgers C, Mundermann A, Riehle H, Dettmers C. (2013). Effects of whole-body vibration training on physical function in patients with multiple sclerosis. NeuroRehabilitation.
54 Holmqvist P, Wallberg M, Hammar M, Landtblom AM, Brynhildsen J. (2006). Symptoms of multiple sclerosis in women in relation to sex steroid exposure. Maturitas.
55 Jones F, Fletcher B. (1996). Occupational factors in multiple sclerosis: An analysis of occupational mortality statistics for men and married women in Great Britain. Neuroepidemiology.
56 Julian LJ, Vella L, Vollmer T, Hadjimichael O, Mohr DC. (2008). Employment in multiple sclerosis. Exiting and re-entering the work force. Journal of Neurology.
57 Khalili M, Eghtesadi S, Mirshafiey A, et al. (2014). Effect of lipoic acid consumption on oxidative stress among multiple sclerosis patients: a randomized controlled clinical trial. Nutritional Neuroscience.
58 Khurana SR, Bamer AM, Turner AP, et al. (2009). The prevalence of overweight and obesity in veterans with multiple sclerosis. American Journal of Physical Medicine & Rehabilitation / Association of Academic Physiatrists.
59 Klaren RE, Hubbard EA, Motl RW. (2014). Efficacy of a Behavioral Intervention for Reducing Sedentary Behavior in Persons with Multiple Sclerosis A Pilot Examination. Am J Prev Med.
60 Klaren RE, Motl RW, Dlugonski D, Sandroff BM, Pilutti LA. (2013). Objectively quantified physical activity in persons with multiple sclerosis. Archives of Physical Medicine and Rehabilitation.
61 Klefbeck B, Hamrah Nedjad J. (2003). Effect of inspiratory muscle training in patients with multiple sclerosis. Archives of Physical Medicine and Rehabilitation.
62 Koch M, Uyttenboogaart M, van Harten A, De Keyser J. (2008). Factors associated with the risk of secondary progression in multiple sclerosis. Mult Scler J.
63 Kremenchutzky M, Rice GPA, Baskerville J, Wingerchuk DM, Ebers GC. (2006). The natural history of multiple sclerosis: a geographically based study - 9: Observations on the progressive phase of the disease. Brain: A Journal of Neurology.
64 Krokavcova M, van Dijk JP, Nagyova I, et al. (2008). Social support as a predictor of perceived health status in patients with multiple sclerosis. Patient Education and Counseling.
65 Kurtzke JF. (1969). Some epidemiologic features compatible with an infectious origin for multiple sclerosis. International Archives of Allergy and Applied Immunology.
66 Kurtzke JF. (1995). MS epidemiology world wide. One view of current status. Acta Neurologica Scandinavica Supplementum.
67 Kurtzke JF. (2000). Epidemiology of multiple sclerosis. Does this really point toward an etiology? Lectio Doctoralis. Neurological Sciences: Official Journal of the Italian Neurological Society and of the Italian Society of Clinical Neurophysiology.
68 Kurtzke JF, Beebe GW, Nagler B, Auth TL, Kurland LT, Nefzger MD. (1968). Studies on natural history of multiple sclerosis. 4. Clinical features of the onset bout. Acta Neurologica Scandinavica.
69 Kurtzke JF, Beebe GW, Norman JE. (1979). Epidemiology of multiple sclerosis in U.S. veterans: 1. Race, sex, and geographic distribution. Neurology.
70 Kurtzke JF, Beebe GW, Norman JE. (1985). Epidemiology of multiple sclerosis in US veterans: III. Migration and the risk of MS. Neurology.
71 Kurtzke JF, Page WF. (1997). Epidemiology of multiple sclerosis in US veterans: VII. Risk factors for MS. Neurology.
72 Kurtzke JF, Page WF, Murphy FM, Norman JE. (1992). Epidemiology of multiple sclerosis in US veterans. 4. Age at onset. Neuroepidemiology.
73 Langer-Gould A, Huang S, Van Den Eeden SK, et al. (2011). Vitamin D, Pregnancy, Breastfeeding, and Postpartum Multiple Sclerosis Relapses. Archives of Neurology.
74 Lauer K. (1994). The risk of multiple sclerosis in the U.S.A. in relation to sociogeographic features: a factor-analytic study. Journal of Clinical Epidemiology.
75 Lavela SL, Prohaska TR, Furner S, Weaver FM. (2012). Chronic diseases in male veterans with multiple sclerosis. Preventing Chronic Disease.
76 Learmonth YC, Paul L, Miller L, Mattison P, McFadyen AK. (2012). The effects of a 12-week leisure centre-based, group exercise intervention for people moderately affected with multiple sclerosis: a randomized controlled pilot study. Clin Rehabil.
77 Leong EM, Semple SJ, Angley M, Siebert W, Petkov J, McKinnon RA. (2009). Complementary and alternative medicines and dietary interventions in multiple sclerosis: What is being used in South Australia and why?. Complementary Therapies in Medicine.
78 Lotfi J, Sahraian MA, Khorramnia S, Ebrahim MM. (2008). Effects of pregnancy on the disease course in Iranian multiple sclerosis patients. Multiple Sclerosis.
79 Lozano-Quilis JA, Gil-Gomez H, Gil-Gomez JA, et al. (2014). Virtual Rehabilitation for Multiple Sclerosis Using a Kinect-Based System: Randomized Controlled Trial. J Med Internet Res.
80 Lucas RM, Ponsonby AL, Dear K, et al. (2011). Sun exposure and vitamin D are independent risk factors for CNS demyelination. Neurology.
81 Mackereth PA, Booth K, Hillier VF, Caress AL. (2009). Reflexology and progressive muscle relaxation training for people with multiple sclerosis: a crossover trial. Complementary Therapies in Clinical Practice.
82 Marandi SM, Nejad VS, Shanazari Z, Zolaktaf V. (2013). A comparison of 12 weeks of pilates and aquatic training on the dynamic balance of women with mulitple sclerosis. International Journal of Preventive Medicine.
83 Marrie RA, Horwitz RI, Cutter G, Tyry T, Vollmer T. (2011). Association between comorbidity and clinical characteristics of MS. Acta Neurologica Scandinavica.
84 McAuley E, Motl RW, Morris KS, et al. (2007). Enhancing physical activity adherence and well-being in multiple sclerosis: a randomised controlled trial. Multiple Sclerosis (Houndmills, Basingstoke, England).
85 McCullagh R, Fitzgerald AP, Murphy RP, Cooke G. (2008). Long-term benefits of exercising on quality of life and fatigue in multiple sclerosis patients with mild disability: a pilot study. Clin Rehabil.
86 McDowell TY, Amr S, Culpepper WJ, et al. (2011). Sun exposure, vitamin D and age at disease onset in relapsing multiple sclerosis. Neuroepidemiology.
87 McDowell TY, Amr S, Langenberg P, et al. (2010). Time of birth, residential solar radiation and age at onset of multiple sclerosis. Neuroepidemiology.
88 Medina-Perez C, de Souza-Teixeira F, Fernandez-Gonzalo R, de Paz-Fernandez JA. (2014). Effects of a resistance training program and subsequent detraining on muscle strength and muscle power in multiple sclerosis patients. NeuroRehabilitation.
89 Mills N, Allen J. (2000). Mindfulness of movement as a coping strategy in multiple sclerosis. A pilot study. Gen Hosp Psychiatry.
90 Mod RW, Snook EM, McAuley E, Scott JA, Gliottoni RC. (2007). Are physical activity and symptoms correlates of functional limitations and disability in multiple sclerosis?. Rehabilitation Psychology.
91 Mohr DC, Goodkin DE, Islar J, Hauser SL, Genain CP. (2001). Treatment of depression is associated with suppression of nonspecific and antigen-specific T(H)1 responses in multiple sclerosis. Archives of Neurology.
92 Morrison W, Nelson J. (1994). Environmental triggers in multiple sclerosis. Fact or fallacy?. Axone.
93 Mostert S, Kesselring J. (2002). Effects of a short-term exercise training program on aerobic fitness, fatigue, health perception and activity level of subjects with multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
94 Motl RW, Dlugonski D, Wojcicki TR, McAuley E, Mohr DC. (2011). Internet intervention for increasing physical activity in persons with multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
95 Motl RW, McAuley E, Snook EM. (2005). Physical activity and multiple sclerosis: a meta-analysis. Multiple Sclerosis (Houndmills, Basingstoke, England).
96 Motl RW, Pilutti LA, Learmonth YC, Goldman MD, Brown T. (2013). Clinical Importance of Steps Taken per Day among Persons with Multiple Sclerosis. PloS One.
97 Munger KL, Chitnis T, Ascherio A. (2009). Body size and risk of MS in two cohorts of US women. Neurology.
98 Negahban H, Rezaie S, Goharpey S. (2013). Massage therapy and exercise therapy in patients with multiple sclerosis: a randomized controlled pilot study. Clin Rehabil.
99 Nelson RE, Xie Y, Kamauu A, Schuerch M, Foskett N, Lafleur J. (2013). Multiple sclerosis increases the risk of infections resulting in a hospitalization among veterans. Value in Health.
100 Neuteboom RF, Janssens AC, Siepman TA, et al. (2012). Pregnancy in multiple sclerosis: clinical and self-report scales. Journal of Neurology.
101 Nilsagard YE, Forsberg AS, von Koch L. (2013). Balance exercise for persons with multiple sclerosis using Wii games: a randomised, controlled multi-centre study. Multiple Sclerosis (Houndmills, Basingstoke, England).
102 Nisipeanu P, Korczyn AD. (1993). Psychological stress as risk factor for exacerbations in multiple sclerosis. Neurology.
103 Norman JE, Cook SD, Dowling PC. (1983). Household pets among veterans with multiple sclerosis and age-matched controls. Pilot survey. Archives of Neurology.
104 Norman JE, Kurtzke JF, Beebe GW. (1983). Epidemiology of multiple sclerosis in U.S. veterans: 2. Latitude, climate and the risk of multiple sclerosis. Journal of Chronic Diseases.
105 O'Connor K, Weinstock-Guttman B, Carl E, Kilanowski C, Zivadinov R, Ramanathan M. (2012). Patterns of dietary and herbal supplement use by multiple sclerosis patients. Journal of Neurology.
106 Oken BS, Kishiyama S, Zajdel D, et al. (2004). Randomized controlled trial of yoga and exercise in multiple sclerosis. Neurology.
107 Page WF, Kurtzke JF, Murphy FM, Norman JE. (1993). Epidemiology of multiple sclerosis in U.S. veterans: V. Ancestry and the risk of multiple sclerosis. Annals of Neurology.
108 Page WF, Mack TM, Kurtzke JF, Murphy FM, Norman JE. (1995). Epidemiology of multiple sclerosis in US veterans. 6. Population ancestry and surname ethnicity as risk factors for multiple sclerosis. Neuroepidemiology.
109 Pilutti LA, Dlugonski D, Sandroff BM, Klaren R, Motl RW. (2014). Randomized controlled trial of a behavioral intervention targeting symptoms and physical activity in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
110 Pilutti LA, Dlugonski D, Sandroff BM, Klaren RE, Motl RW. (2014). Internet-delivered lifestyle physical activity intervention improves body composition in multiple sclerosis: preliminary evidence from a randomized controlled trial. Archives of Physical Medicine and Rehabilitation.
111 Plow M, Bethoux F, Mai K, Marcus B. (2014). A formative evaluation of customized pamphlets to promote physical activity and symptom self-management in women with multiple sclerosis. Health Educ Res.
112 Plow M, Bethoux F, McDaniel C, McGlynn M, Marcus B. (2014). Randomized controlled pilot study of customized pamphlets to promote physical activity and symptom self-management in women with multiple sclerosis. Clin Rehabil.
113 Portaccio E, Ghezzi A, Hakiki B, et al. (2011). Breastfeeding is not related to postpartum relapses in multiple sclerosis. Neurology.
114 Purdey M. (2004). Chronic barium intoxication disrupts sulphated proteoglycan synthesis: a hypothesis for the origins of multiple sclerosis. Medical Hypotheses.
115 Ross RT, Cheang M. (1995). Geographic similarities between varicella and multiple sclerosis: an hypothesis on the environmental factor of multiple sclerosis. Journal of Clinical Epidemiology.
116 Rudick RA, Lee JC, Cutter GR, et al. (2010). Disability progression in a clinical trial of relapsing-remitting multiple sclerosis: eight-year follow-up. Archives of Neurology.
117 Ruiz J, Labas MP, Triche EW, Lo AC. (2013). Combination of robot-assisted and conventional body-weight-supported treadmill training improves gait in persons with multiple sclerosis: a pilot study. Journal of neurologic physical therapy: JNPT.
118 Runia TF, Hop WC, de Rijke YB, Buljevac D, Hintzen RQ. (2012). Lower serum vitamin D levels are associated with a higher relapse risk in multiple sclerosis. Neurology.
119 Sabapathy NM, Minahan CL, Turner GT, Broadley SA. (2011). Comparing endurance- and resistance-exercise training in people with multiple sclerosis: a randomized pilot study. Clin Rehabil.
120 Sadovnick AD, Eisen K, Hashimoto SA, et al. (1994). Pregnancy and multiple sclerosis. A prospective study. Archives of Neurology.
121 Sandroff BM, Klaren RE, Pilutti LA, Dlugonski D, Benedict RH, Motl RW. (2014). Randomized controlled trial of physical activity, cognition, and walking in multiple sclerosis. Journal of Neurology.
122 Sibley WA, Bamford CR, Clark K. (1985). Clinical viral infections and multiple sclerosis. Lancet.
123 Somer E, Golan D, Dishon S, Cuzin-Disegni L, Lavi I, Miller A. (2010). Patients with multiple sclerosis in a war zone: coping strategies associated with reduced risk for relapse. Multiple Sclerosis (Houndmills, Basingstoke, England).
124 Sosnoff JJ, Finlayson M, McAuley E, Morrison S, Motl RW. (2014). Home-based exercise program and fall-risk reduction in older adults with multiple sclerosis: phase 1 randomized controlled trial. Clin Rehabil.
125 Stoll SS, Nieves C, Tabby DS, Schwartzman R. (2012). Use of therapies other than disease-modifying agents, including complementary and alternative medicine, by patients with multiple sclerosis: a survey study. The Journal of the American Osteopathic Association.
126 Straudi S, Benedetti MG, Venturini E, Manca M, Foti C, Basaglia N. (2013). Does robot-assisted gait training ameliorate gait abnormalities in multiple sclerosis? A pilot randomized-control trial. NeuroRehabilitation.
127 Stuifbergen AK, Roberts GJ. (1997). Health promotion practices of women with multiple sclerosis. Archives of Physical Medicine and Rehabilitation.
128 Surakka J, Romberg A, Ruutiainen J, et al. (2004). Effects of aerobic and strength exercise on motor fatigue in men and women with multiple sclerosis: a randomized controlled trial. Clin Rehabil.
129 Sutherland G, Andersen MB, Morris T. (2005). Relaxation and health-related quality of life in multiple sclerosis: the example of autogenic training. Journal of Behavioral Medicine.
130 Sutherland G, Andersen MB, Stoove MA. (2001). Can aerobic exercise training affect health-related quality of life for people with multiple sclerosis?. J Sport Exerc Psychol.
131 Tarakci E, Yeldan I, Huseyinsinoglu BE, Zenginler Y, Eraksoy M. (2013). Group exercise training for balance, functional status, spasticity, fatigue and quality of life in multiple sclerosis: a randomized controlled trial. Clin Rehabil.
132 Tedeholm H, Skoog B, Lisovskaja V, Runmarker B, Nerman O, Andersen O. (2015). The outcome spectrum of multiple sclerosis: disability, mortality, and a cluster of predictors from onset. Journal of Neurology.
133 Tesar N, Bandion K, Baumhackl U. (2005). Efficacy of a neuropsychological training programme for patients with multiple sclerosis -- a randomised controlled trial. Wiener Klinische Wochenschrift.
134 Tinghog P, Bjorkenstam C, Carstensen J, et al. (2014). Co-morbidities increase the risk of disability pension among MS patients: a population-based nationwide cohort study. BMC Neurol.
135 Tosh J, Dixon S, Carter A, et al. (2014). Cost effectiveness of a pragmatic exercise intervention (EXIMS) for people with multiple sclerosis: economic evaluation of a randomised controlled trial. Mult Scler J.
136 Turner AP, Hartoonian N, Maynard C, Leipertz SL, Haselkorn JK. (2014). Examining Health Behaviors and 15 year Mortality among Individuals with Multiple Sclerosis. Archives of Physical Medicine and Rehabilitation.
137 Turner AP, Hartoonian N, Maynard C, Leipertz SL, Haselkorn JK. (2015). Smoking and physical activity: examining health behaviors and 15-year mortality among individuals with multiple sclerosis. Archives of Physical Medicine and Rehabilitation.
138 Turner AP, Hawkins EJ, Haselkorn JK, Kivlahan DR. (2009). Alcohol misuse and multiple sclerosis. Archives of Physical Medicine and Rehabilitation.
139 Turner AP, Kivlahan DR, Haselkorn JK. (2009). Exercise and quality of life among people with multiple sclerosis: looking beyond physical functioning to mental health and participation in life. Archives of Physical Medicine and Rehabilitation.
140 Turner AP, Kivlahan DR, Kazis LE, Haselkorn JK. (2007). Smoking among veterans with multiple sclerosis: prevalence correlates, quit attempts, and unmet need for services. Archives of Physical Medicine and Rehabilitation.
141 Turner AP, Williams RM, Bowen JD, Kivlahan DR, Haselkorn JK. (2006). Suicidal ideation in multiple sclerosis. Archives of Physical Medicine and Rehabilitation.
142 Tyler ME, Kaczmarek KA, Rust KL, Subbotin AM, Skinner KL, Danilov YP. (2014). Non-invasive neuromodulation to improve gait in chronic multiple sclerosis: a randomized double blind controlled pilot trial. J Neuroeng Rehabil.
143 van den Berg M, Dawes H, Wade DT, et al. (2006). Treadmill training for individuals with multiple sclerosis: a pilot randomised trial. Journal of Neurology, Neurosurgery, and Psychiatry.
144 van der Mei IA, Ponsonby AL, Dwyer T, et al. (2003). Past exposure to sun, skin phenotype, and risk of multiple sclerosis: case-control study. BMJ.
145 Vaney C, Gattlen B, Lugon-Moulin V, et al. (2012). Robotic-assisted step training (lokomat) not superior to equal intensity of over-ground rehabilitation in patients with multiple sclerosis. Neurorehabil Neural Repair.
146 Velikonja O, Curic K, Ozura A, Jazbec SS. (2010). Influence of sports climbing and yoga on spasticity, cognitive function, mood and fatigue in patients with multiple sclerosis. Clinical Neurology and Neurosurgery.
147 Wallin MT, Culpepper WJ, Coffman P, et al. (2012). The Gulf War era multiple sclerosis cohort: age and incidence rates by race, sex and service. Brain: A Journal of Neurology.
148 Wallin MT, Kurtzke JF, Culpepper WJ, et al. (2014). Multiple sclerosis in gulf war era veterans. 2. Military deployment and risk of multiple sclerosis in the first gulf war. Neuroepidemiology.
149 Wallin MT, Page WF, Kurtzke JF. (2000). Epidemiology of multiple sclerosis in US veterans. VIII. Long-term survival after onset of multiple sclerosis. Brain: A Journal of Neurology.
150 Wallin MT, Page WF, Kurtzke JF. (2004). Multiple sclerosis in US veterans of the Vietnam era and later military service: race, sex, and geography. Annals of Neurology.
151 Wallin MT, Page WF, Kurtzke JF. (2009). Migration and multiple sclerosis in Alaskan military veterans. Journal of Neurology.
152 Wang L, Li L, Zhang J, Baser O. (2013). Comorbidities and economic burden of multiple sclerosis patients in the united states veteran population. Value in Health.
153 Weikert M, Motl RW, Mohr DC. (2010). Associations among physical activity, stress, disability, and relapse occurrence in multiple sclerosis. Mult Scler J.
154 Weiland TJ, Jelinek GA, Marck CH, et al. (2015). Clinically Significant Fatigue: Prevalence and Associated Factors in an International Sample of Adults with Multiple Sclerosis Recruited via the Internet. PloS One.
155 Widener GL, Allen DD, Gibson-Horn C. (2009). Randomized clinical trial of balance-based torso weighting for improving upright mobility in people with multiple sclerosis. Neurorehabil Neural Repair.
156 Williams RM, Turner AP, Hatzakis M, Bowen JD, Rodriquez AA, Haselkorn JK. (2005). Prevalence and correlates of depression among veterans with multiple sclerosis. Neurology.
157 Yamout B, Itani S, Hourany R, Sibaii AM, Yaghi S. (2010). The effect of war stress on multiple sclerosis exacerbations and radiological disease activity. Journal of the Neurological Sciences.
158 Yildiz M, Tettenborn B, Putzki N. (2011). Vitamin D levels in Swiss multiple sclerosis patients. Swiss Med Wkly.
159 Zeqiraj K, Kruja J, Kabashi S, Mucaj S. (2014). Epidemiological characteristics and functional disability of multiple sclerosis patients in Kosovo. Medicinski Arhiv.

## EXCLUDE: INTERVENTION/EXPOSURE

Publications not reporting on a risk factor of interest:

1 Aisen ML, Sevilla D, Fox N. (1996). Inpatient rehabilitation for multiple sclerosis. J Neurol Rehabil.
2 Akhtar N, Elsetouhy A, Deleu D, et al. (2013). Newly diagnosed multiple sclerosis in state of Qatar. Clinical Neurology and Neurosurgery.
3 Amato MP, Ponziani G. (2000). A prospective study on the prognosis of multiple sclerosis. Neurological sciences: official journal of the Italian Neurological Society and of the Italian Society of Clinical Neurophysiology.
4 Artemiadis AK, Vervainioti AA, Alexopoulos EC, Rombos A, Anagnostouli MC, Darviri C. (2012). Stress management and multiple sclerosis: a randomized controlled trial. Archives of Clinical Neuropsychology: The Official Journal of the National Academy of Neuropsychologists.
5 Ashtari F, Ajalli M, Shaygannejad V, Akbari M, Hovsepian S. (2013). The relation between Vitamin D status with fatigue and depressive symptoms of multiple sclerosis. Journal of research in medical sciences: The Official Journal of Isfahan University of Medical Sciences.
6 Askari F, Ghajarzadeh M, Mohammadifar M, Azimi A, Sahraian MA, Owji M. (2014). Anxiety in patients with multiple sclerosis: association with disability, depression, disease type and sex. Acta Medica Iranica.
7 Baumhackl U, Kappos L, Radue EW, et al. (2005). A randomized, double-blind, placebo-controlled study of oral hydrolytic enzymes in relapsing multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
8 Baumstarck K, Pelletier J, Butzkueven H, et al. (2013). Health-related quality of life as an independent predictor of long-term disability for patients with relapsing-remitting multiple sclerosis. European Journal of Neurology: The Official Journal of the European Federation of Neurological Societies.
9 Benito-Leon J, Mitchell AJ, Rivera-Navarro J, Morales-Gonzalez JM. (2013). Impaired health-related quality of life predicts progression of disability in multiple sclerosis. European journal of neurology: the official journal of the European Federation of Neurological Societies.
10 Bergamaschi R, Berzuini C, Romani A, Cosi V. (2001). Predicting secondary progression in relapsing-remitting multiple sclerosis: a Bayesian analysis. Journal of the Neurological Sciences.
11 Berg-Hansen P, Smestad C, Sandvik L, Harbo HF, Celius EG. (2013). Increased disease severity in non-Western immigrants with multiple sclerosis in Oslo, Norway. European Journal of Neurology.
12 Broadley SA, Vanags D, Williams B, et al. (2009). Results of a phase IIa clinical trial of an anti-inflammatory molecule, chaperonin 10, in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
13 Calabrese M, Romualdi C, Poretto V, et al. (2013). The changing clinical course of multiple sclerosis: a matter of gray matter. Annals of Neurology.
14 Confavreux C, Vukusic S, Moreau T, Adeleine P. (2000). Relapses and progression of disability in multiple sclerosis. N Engl J Med.
15 D'Alisa S, Miscio G, Baudo S, Simone A, Tesio L, Mauro A. (2006). Depression is the main determinant of quality of life in multiple sclerosis: a classification-regression (CART) study. Disability and Rehabilitation.
16 Damasceno A, Von Glehn F, Brandao CO, Damasceno BP, Cendes F. (2013). Prognostic indicators for long-term disability in multiple sclerosis patients. Journal of the Neurological Sciences.
17 Debouverie M, Pittion-Vouyovitch S, Louis S, Guillemin F. (2008). Natural history of multiple sclerosis in a population-based cohort. European Journal of Neurology: The Official Journal of the European Federation of Neurological Societies.
18 D'Hooghe M B, Nagels G, Uitdehaag BM. (2010). Long-term effects of childbirth in MS. Journal of Neurology, Neurosurgery, and Psychiatry.
19 Ehde DM, Kraft GH, Chwastiak L, et al. (2008). Efficacy of paroxetine in treating major depressive disorder in persons with multiple sclerosis. Gen Hosp Psychiatry.
20 Ehrenreich H, Fischer B, Norra C, et al. (2007). Exploring recombinant human erythropoietin in chronic progressive multiple sclerosis. Brain: A Journal of Neurology.
21 El-Salem K, Al-Shimmery E, Horany K, Al-Refai A, Al-Hayk K, Khader Y. (2006). Multiple sclerosis in Jordan: A clinical and epidemiological study. Journal of Neurology.
22 Eriksson M, Andersen O, Runmarker B. (2003). Long-term follow up of patients with clinically isolated syndromes, relapsing-remitting and secondary progressive multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
23 Friedman JE, Zabriskie JB, Plank C, et al. (2005). A randomized clinical trial of valacyclovir in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
24 Guarnaccia JB, Aslan M, O'Connor TZ, et al. (2006). Quality of life for veterans with multiple sclerosis on disease-modifying agents: Relationship to disability. Journal of Rehabilitation Research and Development.
25 Guerra E, di Cagno A, Mancini P, et al. (2014). Physical fitness assessment in multiple sclerosis patients: a controlled study. Research in Developmental Disabilities.
26 Haas J, Hommes OR. (2007). A dose comparison study of IVIG in postpartum relapsing-remitting multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
27 Hughes SE, Spelman T, Gray OM, et al. (2014). Predictors and dynamics of postpartum relapses in women with multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
28 Kaiser CC, Shukla DK, Stebbins GT, et al. (2009). A pilot test of pioglitazone as an add-on in patients with relapsing remitting multiple sclerosis. Journal of Neuroimmunology.
29 Kappos L, Freedman MS, Polman CH, et al. (2007). Effect of early versus delayed interferon beta-1b treatment on disability after a first clinical event suggestive of multiple sclerosis: a 3-year follow-up analysis of the BENEFIT study. Lancet.
30 Karp I, Manganas A, Sylvestre MP, Roger E, Ho A, Duquette P. (2012). The impact of pregnancy on progression of relapsing-remitting multiple sclerosis. Mult Scler J.
31 Kaufman MD, Johnson SK, Moyer D, Bivens J, Norton HJ. (2003). Multiple sclerosis: severity and progression rate in African Americans compared with whites. American Journal of Physical Medicine & Rehabilitation / Association of Academic Physiatrists.
32 Keyhanian K, Davoudi V, Etemadifar M, Amin M. (2012). Better prognosis of multiple sclerosis in patients who experienced a full-term pregnancy. European Neurology.
33 Khaleeli Z, Ciccarelli O, Manfredonia F, et al. (2008). Predicting progression in primary progressive multiple sclerosis: a 10-year multicenter study. Annals of Neurology.
34 Kimball SM, Ursell MR, O'Connor P, Vieth R. (2007). Safety of vitamin D3 in adults with multiple sclerosis. The American Journal of Clinical Nutrition.
35 Koch M, Mostert J, Heerings M, Uyttenboogaart M, De Keyser J. (2009). Fatigue, depression and disability accumulation in multiple sclerosis: a cross-sectional study. European Journal of Neurology.
36 Koch M, Ramsaransing GS, Fokkema MR, Heersema DJ, De Keyser J. (2006). Erythrocyte membrane fatty acids in benign and progressive forms of multiple sclerosis. Journal of the Neurological Sciences.
37 Koch M, Uyttenboogaart M, Heerings M, Heersema D, Mostert J, De Keyser J. (2008). Progression in familial and nonfamilial MS. Multiple Sclerosis (Houndmills, Basingstoke, England).
38 Koch M, Uyttenboogaart M, Heersema D, Steen C, De Keyser J. (2009). Parity and secondary progression in multiple sclerosis. Journal of Neurology, Neurosurgery, and Psychiatry.
39 Koch M, Uyttenboogaart M, van Harten A, Heerings M, De Keyser J. (2008). Fatigue, depression and progression in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
40 Koch MW, Patten S, Berzins S, et al. (2015). Depression in multiple sclerosis: A long-term longitudinal study. Multiple Sclerosis (Houndmills, Basingstoke, England).
41 Kochs L, Wegener S, Suhnel A, Voigt K, Zettl UK. (2014). The use of complementary and alternative medicine in patients with multiple sclerosis: a longitudinal study. Complementary Therapies in Medicine.
42 Kurtzke JF, Auth TL, Beebe GW, Kurland LT, Nagler B, Nefzger MD. (1969). Survival in multiple sclerosis. Transactions of the American Neurological Association.
43 Kurtzke JF, Beebe GW, Nagler B, Nefzger MD, Auth TL, Kurland LT. (1970). Studies on the natural history of multiple sclerosis. V. Long-term survival in young men. Archives of Neurology.
44 Lambert CP, Lee Archer R, Evans WJ. (2002). Body composition in ambulatory women with multiple sclerosis. Archives of Physical Medicine and Rehabilitation.
45 Lincoln NB, Yuill F, Holmes J, et al. (2011). Evaluation of an adjustment group for people with multiple sclerosis and low mood: a randomized controlled trial. Multiple Sclerosis (Houndmills, Basingstoke, England).
46 Locke S, Kruper DC, Yakovlev PI. (1964). FIVE-YEAR FOLLOW-UP ON MULTIPLE SCLEROSIS. REPORT ON VETERANS ADMINISTRATION COOPERATIVE STUDY. Archives of Neurology.
47 Lucas RM, Hughes AM, Lay ML, et al. (2011). Epstein-Barr virus and multiple sclerosis. Journal of Neurology, Neurosurgery, and Psychiatry.
48 Mandel M, Gauthier SA, Guttmann CRG, Weiner HL, Betensky RA. (2007). Estimating time to event from longitudinal categorical data: An analysis of multiple sclerosis progression. J Am Stat Assoc.
49 Marrie RA, Horwitz R, Cutter G, Tyry T, Campagnolo D, Vollmer T. (2009). Comorbidity delays diagnosis and increases disability at diagnosis in MS. Neurology.
50 Marrie RA, Rudick R, Horwitz R, et al. (2010). Vascular comorbidity is associated with more rapid disability progression in multiple sclerosis. Neurology.
51 Masera S, Cavalla P, Prosperini L, et al. (2014). Parity is associated with a longer time to reach irreversible disability milestones in women with multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
52 Masera S, Prosperini L, Petsas N, et al. (2008). Multiple sclerosis and pregnancy: relationship with progression of disability. Multiple Sclerosis.
53 Mastorodemos V, Nikolakaki H, Tzagournissakis M, et al. (2010). Benign multiple sclerosis in Crete. Multiple Sclerosis (Houndmills, Basingstoke, England).
54 Menzin J, Caon C, Nichols C, White LA, Friedman M, Pill MW. (2013). Narrative Review of the Literature on Adherence to Disease-Modifying Therapies Among Patients with Multiple Sclerosis. Journal of Managed Care Pharmacy.
55 Milanlioglu A, Ozdemir PG, Cilingir V, Gulec TC, Aydin MN, Tombul T. (2014). Coping strategies and mood profiles in patients with multiple sclerosis. Arq Neuropsiquiatr.
56 Mitsonis CI, Zervas IM, Potagas CM, et al. (2010). Effects of escitalopram on stress-related relapses in women with multiple sclerosis: an open-label, randomized, controlled, one-year follow-up study. European Neuropsychopharmacology: The Journal of the European College of Neuropsychopharmacology.
57 Moghaddasi M, Mamarabadi M, Mohebi N, Razjouyan H, Aghaei M. (2013). Homocysteine, vitamin B12 and folate levels in Iranian patients with Multiple Sclerosis: A case control study. Clinical Neurology and Neurosurgery.
58 Mohr DC, Boudewyn AC, Goodkin DE, Bostrom A, Epstein L. (2001). Comparative outcomes for individual cognitive-behavior therapy, supportive-expressive group psychotherapy, and sertraline for the treatment of depression in multiple sclerosis. Journal of Consulting and Clinical Psychology.
59 Mohr DC, Hart S, Vella L. (2007). Reduction in disability in a randomized controlled trial of telephone-administered cognitive-behavioral therapy. Health psychology: official journal of the Division of Health Psychology, American Psychological Association.
60 Mutluay FK, Demir R, Ozyilmaz S, Caglar AT, Altintas A, Gurses HN. (2007). Breathing-enhanced upper extremity exercises for patients with multiple sclerosis. Clin Rehabil.
61 Nelson RE, Xie Y, Du Vall SL, et al. (2013). Multiple sclerosis subtypes and infections resulting in a hospitalization in the veterans health administration. Pharmacoepidemiology and Drug Safety.
62 Patti F, Ciancio MR, Cacopardo M, et al. (2003). Effects of a short outpatient rehabilitation treatment on disability of multiple sclerosis patients--a randomised controlled trial. Journal of Neurology.
63 Patti F, Ciancio MR, Reggio E, et al. (2002). The impact of outpatient rehabilitation on quality of life in multiple sclerosis. Journal of Neurology.
64 Pilutti LA. (2013). Adapted exercise interventions for persons with progressive multiple sclerosis. Applied Physiology, Nutrition, and Metabolism = Physiologie Appliquee, Nutrition et Metabolisme.
65 Pilutti LA, Lelli DA, Paulseth JE, et al. (2011). Effects of 12 weeks of supported treadmill training on functional ability and quality of life in progressive multiple sclerosis: a pilot study. Archives of Physical Medicine and Rehabilitation.
66 Pittock SJ, Mayr WT, McClelland RL, et al. (2004). Change in MS-related disability in a population-based cohort: a 10-year follow-up study. Neurology.
67 Pohlau D, Przuntek H, Sailer M, et al. (2007). Intravenous immunoglobulin in primary and secondary chronic progressive multiple sclerosis: a randomized placebo controlled multicentre study. Multiple Sclerosis (Houndmills, Basingstoke, England).
68 Ponichtera JA, Rodgers MM, Glaser RM, Mathews TA, Camaione DN. (1992). Concentric and eccentric isokinetic lower extremity strength in persons with multiple sclerosis. The Journal of Orthopaedic and Sports Physical Therapy.
69 Pozzilli C, Palmisano L, Mainero C, et al. (2004). Relationship between emotional distress in caregivers and health status in persons with multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
70 Ramagopalan S, Yee I, Byrnes J, Guimond C, Ebers G, Sadovnick D. (2012). Term pregnancies and the clinical characteristics of multiple sclerosis: a population based study. Journal of Neurology, Neurosurgery, and Psychiatry.
71 Riise T, Gronning M, Fernandez O, et al. (1992). Early prognostic factors for disability in multiple sclerosis, a European multicenter study. Acta Neurologica Scandinavica.
72 Rinker IJR, Cossey TC, Cutter GR, Culpepper WJ. (2013). A retrospective review of lithium usage in veterans with multiple sclerosis. Multiple Sclerosis and Related Disorders.
73 Romberg A, Virtanen A, Aunola S, Karppi SL, Karanko H, Ruutiainen J. (2004). Exercise capacity, disability and leisure physical activity of subjects with multiple sclerosis. Multiple sclerosis (Houndmills, Basingstoke, England).
74 Roullet E, Verdier-Taillefer MH, Amarenco P, Gharbi G, Alperovitch A, Marteau R. (1993). Pregnancy and multiple sclerosis: a longitudinal study of 125 remittent patients. Journal of Neurology, Neurosurgery, and Psychiatry.
75 Runmarker B, Andersen O. (1995). Pregnancy is associated with a lower risk of onset and a better prognosis in multiple sclerosis. Brain: A Journal of Neurology.
76 Runmarker B, Andersson C, Oden A, Andersen O. (1994). Prediction of outcome in multiple sclerosis based on multivariate models. Journal of Neurology.
77 Salhofer-Polanyi S, Windt J, Sumper H, et al. (2013). Benefits of inpatient multidisciplinary rehabilitation in multiple sclerosis. NeuroRehabilitation.
78 Samonds RJ, Cammermeyer M. (1989). Perceptions of body image in subjects with multiple sclerosis: a pilot study. The Journal of Neuroscience Nursing: Journal of the American Association of Neuroscience Nurses.
79 Sarraf P, Azizi S, Moghaddasi AN, Sahraian MA, Tafakhori A, Ghajarzadeh M. (2014). Relationship between Sleep Quality and Quality of Life in Patients with Multiple Sclerosis. International Journal of Preventive Medicine.
80 Schroeder B, Doig J, Premkumar K. (2014). The effects of massage therapy on multiple sclerosis patients' quality of life and leg function. Evidence-based Complementary and Alternative Medicine: eCAM.
81 Schwartz CE, Foley FW, Rao SM, Bernardin LJ, Lee H, Genderson MW. (1999). Stress and course of disease in multiple sclerosis. Behavioral Medicine (Washington, D.C.).
82 Sorgun MH, Yucesan C, Tegin C. (2014). Is malnutrition a problem for multiple sclerosis patients?. Journal of Clinical Neuroscience: Official Journal of the Neurosurgical Society of Australasia.
83 Stenager E, Stenager EN, Jensen K. (1994). Effect of pregnancy on the prognosis for multiple sclerosis. A 5-year follow up investigation. Acta Neurologica Scandinavica.
84 Stroud N, Minahan C, Sabapathy S. (2009). The perceived benefits and barriers to exercise participation in persons with multiple sclerosis. Disability and Rehabilitation.
85 Tan H, Cai Q, Agarwal S, Stephenson JJ, Kamat S. (2011). Impact of adherence to disease-modifying therapies on clinical and economic outcomes among patients with multiple sclerosis. Advances in Therapy.
86 Tavee J, Rensel M, Planchon SM, Butler RS, Stone L. (2011). Effects of meditation on pain and quality of life in multiple sclerosis and peripheral neuropathy: a pilot study. International Journal of MS Care.
87 Terzi M, Kocamanoglu B, Guz H, Onar M. (2009). The Eating Attitudes in Multiple Sclerosis Patients. J Neurol Sci-Turk.
88 Teter B, Apatoff B, Coyle P, et al. (2011). Pregnancy Related to Disability Outcomes for Women with Progressive Multiple Sclerosis. Neurology.
89 Thompson DS, Nelson LM, Burns A, Burks JS, Franklin GM. (1986). The effects of pregnancy in multiple sclerosis: a retrospective study. Neurology.
90 Tremlett H, Paty D, Devonshire V. (2005). The natural history of primary progressive MS in British Columbia, Canada. Neurology.
91 Tremlett H, Yinshan Z, Devonshire V. (2008). Natural history of secondary-progressive multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
92 Tremlett HL, Wiles CM, Luscombe DK. (2000). Nonprescription medicine use in a multiple sclerosis clinic population. British Journal of Clinical Pharmacology.
93 Trojano M, Avolio C, Manzari C, et al. (1995). Multivariate analysis of predictive factors of multiple sclerosis course with a validated method to assess clinical events. Journal of Neurology, Neurosurgery, and Psychiatry.
94 Trojano M, Pellegrini F, Paolicelli D, et al. (2009). Real-life impact of early interferon beta therapy in relapsing multiple sclerosis. Annals of Neurology.
95 van der Linden ML, Bulley C, Geneen LJ, Hooper JE, Cowan P, Mercer TH. (2014). Pilates for people with multiple sclerosis who use a wheelchair: feasibility, efficacy and participant experiences. Disability and Rehabilitation.
96 Verdru P, Theys P, D'Hooghe MB, Carton H. (1994). Pregnancy and multiple sclerosis: the influence on long term disability. Clinical Neurology and Neurosurgery.
97 Villoslada P, Arrondo G, Sepulcre J, Alegre M, Artieda J. (2009). Memantine induces reversible neurologic impairment in patients with MS. Neurology.
98 Vukusic S, Confavreux C. (2003). Prognostic factors for progression of disability in the secondary progressive phase of multiple sclerosis. Journal of the Neurological Sciences.
99 Wade DT, Young CA, Chaudhuri KR, Davidson DL. (2002). A randomised placebo controlled exploratory study of vitamin B-12, lofepramine, and L-phenylalanine (the “Cari Loder regime”) in the treatment of multiple sclerosis. Journal of Neurology, Neurosurgery, and Psychiatry.
100 Weinshenker BG, Hader W, Carriere W, Baskerville J, Ebers GC. (1989). The influence of pregnancy on disability from multiple sclerosis: a population-based study in Middlesex County, Ontario. Neurology.
101 Weinshenker BG, Rice GP, Noseworthy JH, Carriere W, Baskerville J, Ebers GC. (1991). The natural history of multiple sclerosis: a geographically based study. 3. Multivariate analysis of predictive factors and models of outcome. Brain: A Journal of Neurology.
102 Woessner R, Grauer MT, Frese A, et al. (2006). Long-term antibiotic treatment with roxithromycin in patients with multiple sclerosis. Infection.
103 Worthington J, Jones R, Crawford M, Forti A. (1994). Pregnancy and multiple sclerosis--a 3-year prospective study. Journal of Neurology.
104 Yamout B, Itani S, Arabi A, Hamzeh D, Yaghi S. (2010). Prognostic factors of multiple sclerosis in Lebanon. The International Journal of Neuroscience.
105 Zajicek J, Ball S, Wright D, et al. (2013). Effect of dronabinol on progression in progressive multiple sclerosis (CUPID): a randomised, placebo-controlled trial. The Lancet Neurology.

## EXCLUDE: DESIGN

Publications not meeting study design inclusion criteria:

1 Amezcua L, Chung RH, Conti DV, Langer-Gould AM. (2012). Vitamin D levels in Hispanics with multiple sclerosis. Journal of Neurology.
2 Anens E, Emtner M, Zetterberg L, Hellstrom K. (2014). Physical activity in subjects with multiple sclerosis with focus on gender differences: a survey. BMC Neurol.
3 Bamford CR, Sibley WA, Laguna JF. (1978). Swine influenza vaccination in patients with multiple sclerosis. Archives of Neurology.
4 Bhargava P, Cassard S, Steele SU, et al. (2014). The vitamin D to ameliorate multiple sclerosis (VIDAMS) trial: study design for a multicenter, randomized, double-blind controlled trial of vitamin D in multiple sclerosis. Contemporary Clinical Trials.
5 Brichetto G, Rinaldi S, Spallarossa P, Battaglia MA, de Carvalho ML. (2013). Efficacy of physical therapy in multiple sclerosis as measured with the modified fatigue impact scale and ambulation index: a retrospective study. NeuroRehabilitation.
6 D'Hooghe MB, De Keyser J. (2014). Multiparity in women with multiple sclerosis causes less long-term disability: Yes. Mult Scler J.
7 Esparza ML, Sasaki S, Kesteloot H. (1995). Nutrition, latitude, and multiple sclerosis mortality: an ecologic study. American Journal of Epidemiology.
8 Farinotti M, Simi S, Di Pietrantonj C, et al. (2007). Dietary interventions for multiple sclerosis. Cochrane Database Syst Rev.
9 Freedman DM, Dosemeci H, Alavanja MCR. (2000). Mortality from multiple sclerosis and exposure to residential and occupational solar radiation: a case-control study based on death certificates. Occup Environ Med.
10 Goodin DS. (2008). The impact of war-stress on MS exacerbations. Annals of neurology.
11 Grant WB. (2006). Epidemiology of disease risks in relation to vitamin D insufficiency. Prog Biophys Mol Biol.
12 Griffith G, Klaren RE, Motl RW, Baynard T, Fernhall B. (2015). Experimental protocol of a randomized controlled clinical trial investigating exercise, subclinical atherosclerosis, and walking mobility in persons with multiple sclerosis. Contemporary Clinical Trials.
13 Heine M, Hoogervorst EL, Hacking HG, Verschuren O, Kwakkel G. (2014). Validity of maximal exercise testing in people with multiple sclerosis and low to moderate levels of disability. Physical Therapy.
14 Holmoy T, Kampman MT. (2010). Alaska, multiple sclerosis, and the vitamin D hypothesis. Journal of Neurology.
15 Kileff J, Ashburn A. (2005). A pilot study of the effect of aerobic exercise on people with moderate disability multiple sclerosis. Clin Rehabil.
16 Kurtzke JF. (2008). Some contributions of the Department of Veterans Affairs to the epidemiology of multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
17 Mason RR, Cochrane DJ, Denny GJ, Firth EC, Stannard SR. (2012). Is 8 weeks of side-alternating whole-body vibration a safe and acceptable modality to improve functional performance in multiple sclerosis?. Disability and Rehabilitation.
18 McCombe PA, Callaway LK. (2014). Multiparity in women with multiple sclerosis causes less long-term disability: No. Mult Scler J.
19 Munoz-Lasa S, Ferriero G, Valero R, Gomez-Muniz F, Rabini A, Varela E. (2011). Effect of therapeutic horseback riding on balance and gait of people with multiple sclerosis. Giornale Italiano di Medicina del Lavoro ed Ergonomia.
20 Namaka M, Turcotte D, Leong C, Grossberndt A, Klassen D. (2008). Multiple sclerosis: Etiology and treatment strategies. Consultant Pharmacist.
21 Nordvik I, Myhr KM, Nyland H, Bjerve KS. (2000). Effect of dietary advice and n-3 supplementation in newly diagnosed MS patients. Acta Neurologica Scandinavica.
22 Ozgocmen S, Bulut S, Ilhan N, Gulkesen A, Ardicoglu O, Ozkan Y. (2005). Vitamin D deficiency and reduced bone mineral density in multiple sclerosis: effect of ambulatory status and functional capacity. Journal of Bone and Mineral Metabolism.
23 Pariser G, Madras D, Weiss E. (2006). Outcomes of an aquatic exercise program including aerobic capacity, lactate threshold, and fatigue in two individuals with multiple sclerosis. Journal of neurologic physical therapy: JNPT.
24 Pimentel ML. (2013). Multiple sclerosis in the Southern and Northern hemispheres: the month of birth at different latitudes has the same influence on the prevalence and progression of the disease in the Northern and Southern hemispheres?. Arq Neuropsiquiatr.
25 Poser S, Wikstrom J, Bauer HJ. (1979). Clinical data and the identification of special forms of multiple sclerosis in 1271 cases studied with a standardized documentation system. Journal of the Neurological Sciences.
26 Singh V, Hintzen RQ, Luider TM, Stoop MP. (2012). Proteomics technologies for biomarker discovery in multiple sclerosis. Journal of Neuroimmunology.
27 Smolders J, Hupperts R, Barkhof F, et al. (2011). Efficacy of vitamin D3 as add-on therapy in patients with relapsing-remitting multiple sclerosis receiving subcutaneous interferon beta-1a: a Phase II, multicenter, double-blind, randomized, placebo-controlled trial. Journal of the Neurological Sciences.
28 Torkildsen O, Grytten N, Aarseth J, Myhr KM, Kampman MT. (2012). Month of birth as a risk factor for multiple sclerosis: an update. Acta Neurologica Scandinavica Supplementum.
29 Vukusic S, Confavreux C. (2006). Pregnancy and multiple sclerosis: the children of PRIMS. Clinical Neurology and Neurosurgery.
30 Wingerchuk DM, Lesaux J, Rice GP, Kremenchutzky M, Ebers GC. (2005). A pilot study of oral calcitriol (1,25-dihydroxyvitamin D3) for relapsing-remitting multiple sclerosis. Journal of Neurology, Neurosurgery, and Psychiatry.
31 Wojcicki TR, Roberts SA, Learmonth YC, et al. (2014). Improving physical functional and quality of life in older adults with multiple sclerosis via a DVD-delivered exercise intervention: a study protocol. BMJ Open.
32 Yadav V, Bever C, Bowen J, et al. (2014). Summary of evidence-based guideline: complementary and alternative medicine in multiple sclerosis: report of the guideline development subcommittee of the American Academy of Neurology. Neurology.

## EXCLUDE: PARTICIPANTS

Excluded publications not reporting on participants with MS and risk factor studies excluding progressive MS:

1 Harandi AA, Shahbeigi S, Pakdaman H, Fereshtehnejad SM, Nikravesh E, Jalilzadeh R. (2012). Association of serum 25(OH) vitamin D3 concentration with severity of multiple sclerosis. Iranian Journal of Neurology.
2 Henderson VW. (2007). Alzheimer's disease and other neurological disorders. Climacteric.

## EXCLUDE: LANGUAGE

Excluded non-English language publications:

1 Ragonese P, Castiglia G, Cusimano V, Battaglieri F, Salemi G. (2007). Cigarette smoking, coffee consumption and multiple sclerosis risk: A case - Control study. Acta Medica Mediterranea.

## EXCLUDE: DUPLICATE

Duplicate publications:

1 Sandroff BM, Klaren RE, Pilutti LA, Dlugonski D, Benedict RHB, Motl RW. (2014). Randomized controlled trial of physical activity, cognition, and walking in multiple sclerosis. Journal of Neurology.

## BACKGROUND

Reviews screened for additional references and multiple publications of included studies:

1 (2014). Multiple sclerosis - management of multiple sclerosis in primary and secondary care.
2 Ascherio A. (2013). Environmental factors in multiple sclerosis. Expert Review of Neurotherapeutics.
3 Ascherio A, Munger K, White R, et al. (2013). Vitamin D as a predictor of multiple sclerosis activity and progression. Mult Scler J.
4 Bowling AC, Stewart TM. (2003). Current Complementary and Alternative Therapies for Multiple Sclerosis. Curr Treat Options Neurol.
5 Carrithers MD. (2014). Update on Disease-Modifying Treatments for Multiple Sclerosis. Clinical Therapeutics.
6 Compston A, Coles A. (2002). Multiple sclerosis. Lancet.
7 Constantinescu C, Manouchehrinia A, Tench C, Bibani R, Britton J. (2012). Cigarette Smoking and Disease Progression in Patients with Multiple Sclerosis: A Study of a Large United Kingdom Cohort. Neurology.
8 Dalgas U, Stenager E. (2012). Exercise and disease progression in multiple sclerosis: can exercise slow down the progression of multiple sclerosis?. Therapeutic Advances in Neurological Disorders.
9 Dalgas U, Stenager E, Sloth M, Stenager E. (2015). The effect of exercise on depressive symptoms in multiple sclerosis based on a meta-analysis and critical review of the literature. European Journal of Neurology: The Official Journal of the European Federation of Neurological Societies.
10 D'Hooghe M B, Haentjens P, Nagels G, D'Hooghe T, De Keyser J. (2012). Menarche, oral contraceptives, pregnancy and progression of disability in relapsing onset and progressive onset multiple sclerosis. Journal of Neurology.
11 D'Hooghe M B, Haentjens P, Nagels G, Garmyn M, De Keyser J. (2012). Sunlight exposure and sun sensitivity associated with disability progression in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
12 D'Hooghe M B, Nagels G, Bissay V, De Keyser J. (2010). Modifiable factors influencing relapses and disability in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
13 D'Hooghe M B, Nagels G, De Keyser J, Haentjens P. (2013). Self-reported health promotion and disability progression in multiple sclerosis. Journal of the Neurological Sciences.
14 Faridar A, Eskandari G, Sahraian MA, Minagar A, Azimi A. (2012). Vitamin D and multiple sclerosis: a critical review and recommendations on treatment. Acta Neurol Belg.
15 Farinotti M, Vacchi L, Simi S, Di Pietrantonj C, Brait L, Filippini G. (2012). Dietary interventions for multiple sclerosis. Cochrane Database Syst Rev.
16 Feinstein A, Dalgas U. (2014). The benefits of exercise in progressive MS: some cautious optimism. Multiple Sclerosis (Houndmills, Basingstoke, England).
17 Handel AE, Williamson AJ, Disanto G, Dobson R, Giovannoni G, Ramagopalan SV. (2011). Smoking and multiple sclerosis: an updated meta-analysis. PloS One.
18 Haselkorn JK. (2006). Veterans Health Administration Multiple Sclerosis Centers of Excellence: Clinical care, education, informatics, and research. Journal of Rehabilitation Research and Development.
19 Herndon RM. (2002). Medical hypothesis: why secondary progressive multiple sclerosis is a relentlessly progressive illness. Archives of Neurology.
20 Hutchinson M. (2014). Multiparity in women with multiple sclerosis causes less long-term disability: Commentary. Mult Scler J.
21 Jagannath VA, Fedorowicz Z, Asokan GV, Robak EW, Whamond L. (2010). Vitamin D for the management of multiple sclerosis. Cochrane Database Syst Rev.
22 James E, Dobson R, Kuhle J, Baker D, Giovannoni G, Ramagopalan SV. (2013). The effect of vitamin D-related interventions on multiple sclerosis relapses: a meta-analysis. Mult Scler J.
23 Kuhlmann T, Lingfeld G, Bitsch A, Schuchardt J, Bruck W. (2002). Acute axonal damage in multiple sclerosis is most extensive in early disease stages and decreases over time. Brain: A Journal of Neurology.
24 Kurland LT, Molgaard CA, Kurland EM, Wiederholt WC, Kirkpatrick JW. (1984). Swine flu vaccine and multiple sclerosis. JAMA.
25 Kurtzke JF. (1994). Clinical definition for multiple sclerosis treatment trials. Annals of Neurology.
26 Levin AB, Hadgkiss EJ, Weiland TJ, Jelinek GA. (2014). Meditation as an adjunct to the management of multiple sclerosis. Neurology Research International.
27 Levin AB, Hadgkiss EJ, Weiland TJ, et al. (2014). Can meditation influence quality of life, depression, and disease outcome in multiple sclerosis? Findings from a large international web-based study. Behavioural Neurology.
28 Lublin FD, Reingold SC, Cohen JA, et al. (2014). Defining the clinical course of multiple sclerosis: the 2013 revisions. Neurology.
29 Manouchehrinia A, Weston M, Tench CR, Britton J, Constantinescu CS. (2014). Tobacco smoking and excess mortality in multiple sclerosis: a cohort study. Journal of Neurology, Neurosurgery, and Psychiatry.
30 Marck CH, Hadgkiss EJ, Weiland TJ, van der Meer DM, Pereira NG, Jelinek GA. (2014). Physical activity and associated levels of disability and quality of life in people with multiple sclerosis: a large international survey. BMC Neurol.
31 Marrie RA, Cutter G, Tyry T. (2011). Substantial adverse association of visual and vascular comorbidities on visual disability in multiple sclerosis. Mult Scler J.
32 Marrie RA, Hanwell H. (2013). General health issues in multiple sclerosis: comorbidities, secondary conditions, and health behaviors. Continuum (Minneapolis, Minn).
33 Marrie RA, Horwitz RI. (2010). Emerging effects of comorbidities on multiple sclerosis. The Lancet Neurology.
34 McDonald WI, Compston A, Edan G, et al. (2001). Recommended diagnostic criteria for multiple sclerosis: guidelines from the International Panel on the diagnosis of multiple sclerosis. Annals of Neurology.
35 Miller DH, Fazekas F, Montalban X, Reingold SC, Trojano M. (2014). Pregnancy, sex and hormonal factors in multiple sclerosis. Multiple Sclerosis (Houndmills, Basingstoke, England).
36 Motl RW, McAuley E, Sandroff BM. (2013). Longitudinal change in physical activity and its correlates in relapsing-remitting multiple sclerosis. Physical Therapy.
37 Octavia JR, Coninx K. (2014). Adaptive Personalized Training Games for Individual and Collaborative Rehabilitation of People with Multiple Sclerosis. Biomed Res Int.
38 Overs S, Hughes CM, Haselkorn JK, Turner AP. (2012). Modifiable comorbidities and disability in multiple sclerosis. Current Neurology and Neuroscience Reports.
39 Pilutti LA, Platta ME, Motl RW, Latimer-Cheung AE. (2014). The safety of exercise training in multiple sclerosis: A systematic review. Journal of the Neurological Sciences.
40 Poser CM, Paty DW, Scheinberg L, et al. (1983). New diagnostic criteria for multiple sclerosis: guidelines for research protocols. Annals of Neurology.
41 Pozuelo-Moyano B, Benito-Leon J, Mitchell AJ, Hernandez-Gallego J. (2013). A systematic review of randomized, double-blind, placebo-controlled trials examining the clinical efficacy of vitamin D in multiple sclerosis. Neuroepidemiology.
42 Rezapour-Firouzi S, Arefhosseini SR, Mehdi F, et al. (2013). Immunomodulatory and therapeutic effects of Hot-nature diet and co-supplemented hemp seed, evening primrose oils intervention in multiple sclerosis patients. Complementary Therapies in Medicine.
43 Rietberg MB, Brooks D, Uitdehaag BMJ, Kwakkel G. (2005). Exercise therapy for multiple sclerosis - art. no. CD003980.pub2. Cochrane Database Syst Rev.
44 Romberg A, Virtanen A, Ruutiainen J. (2005). Long-term exercise improves functional impairment but not quality of life in multiple sclerosis. Journal of Neurology.
45 Sa MJ. (2014). Exercise therapy and multiple sclerosis: a systematic review. Journal of Neurology.
46 Schwarz S, Leweling H. (2005). Multiple sclerosis and nutrition. Multiple Sclerosis (Houndmills, Basingstoke, England).
47 Simpson R, Booth J, Lawrence M, Byrne S, Mair F, Mercer S. (2014). Mindfulness based interventions in multiple sclerosis--a systematic review. BMC Neurol.
48 Stellmann JP, Neuhaus A, Lederer C, Daumer M, Heesen C. (2014). Validating predictors of disease progression in a large cohort of primary-progressive multiple sclerosis based on a systematic literature review. PloS One.
49 Swank RL. (1991). Multiple sclerosis: fat-oil relationship. Nutrition.
50 Swank RL, Goodwin J. (2003). Review of MS patient survival on a Swank low saturated fat diet. Nutrition.
51 Toomey E, Coote SB. (2012). Physical rehabilitation interventions in nonambulatory people with multiple sclerosis: a systematic review. International Journal of Rehabilitation Research Internationale Zeitschrift fur Rehabilitationsforschung. Revue Internationale de Recherches de Readaptation.
52 Tremlett HL, Devonshire VA. (2006). Does the season or month of birth influence disease progression in multiple sclerosis?. Neuroepidemiology.
53 Vukusic S, Hutchinson M, Hours M, et al. (2004). Pregnancy and multiple sclerosis (the PRIMS study): clinical predictors of post-partum relapse. Brain: A Journal of Neurology.
54 Wallin MT, Wilken JA, Turner AP, Williams RM, Kane R. (2006). Depression and multiple sclerosis: Review of a lethal combination. Journal of Rehabilitation Research and Development.
55 Wergeland S, Torkildsen O, Bo L, Myhr KM. (2012). Polyunsaturated fatty acids in multiple sclerosis therapy. Acta Neurologica Scandinavica.
56 Wier LM, Hatcher MS, Triche EW, Lo AC. (2011). Effect of robot-assisted versus conventional body-weight-supported treadmill training on quality of life for people with multiple sclerosis. Journal of Rehabilitation Research and Development.
57 Wingerchuk DM. (2012). Smoking: effects on multiple sclerosis susceptibility and disease progression. Ther Adv Neurol Disord.
58 Yeh EA, Weinstock-Guttman B. (2010). Multiple sclerosis: predicting risk and delaying progression. The Lancet. Neurology.