# APPENDIX A SEARCH STRATEGIES

This appendix documents the exact search strings for all searched electronic databases. We designed a search strategy for each key question in order to maximize relevance and retrieval success.

## SEARCH METHODOLOGY KQ1

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – ∼1946-2/27/2015

LANGUAGE:

English

SEARCH STRATEGY #1 (Study Design Filter):

multiple sclerosis[tiab] OR multiple sclerosis[majr]

AND

progression[tiab] OR progressive[tiab] OR progressing[tiab] OR mortality[tiab] OR disease course[tiab] OR disability[tiab]

AND

“cohort studies”[mh] OR “follow-up studies”[mh] OR prognos^*^[tiab] OR predict^*^[tiab] OR multivariate[tiab]

NOT

(animal OR animals) NOT (human OR humans)

SEARCH STRATEGY #2 (Risk Factor Filter):

multiple sclerosis[tiab] OR multiple sclerosis[majr]

AND

progression[tiab] OR progressive[tiab] OR progressing[tiab] OR mortality[tiab] OR disease course[tiab] OR disability[tiab]

AND

geographic[tiab] OR sun exposure[tiab] OR vitamin D[tiab] OR fatty acid[tiab] OR diet[tiab] OR dietary[tiab] OR nutrition^*^[tiab] OR obesity[tiab] OR smoking[tiab] OR tobacco[tiab] OR alcohol[tiab] OR exercise[tiab] OR physical activity[tiab] OR stress[tiab] OR anesthesia[tiab] OR radiation therapy[tiab] OR oral contraception[tiab] OR fertility treatment[tiab] OR pregnan^*^[tiab] OR delivery[tiab] OR breastfeeding[tiab] OR salt intake[tiab] OR milk[tiab] OR water[tiab] OR trace elements[tiab] OR trauma[tiab] OR traumatic[tiab] OR Epstein–Barr virus[tiab]

NOT

(animal OR animals) NOT (human OR humans)

DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science– Indexes = SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH - 1980-2/27/2015

LANGUAGE:

English

SEARCH STRATEGY #1:

TS = (multiple sclerosis)

AND

TS = (progression OR progressive OR progressing)

AND

TS = (cohort OR prognos^*^OR predict^*^ OR multivariate)

SEARCH STRATEGY #2:

TS = (multiple sclerosis)

AND

TS = (progression OR progressive OR progressing)

AND

TS = (geographic OR sun OR sunlight OR vitamin D OR fatty acid OR diet OR dietary OR nutrition^*^ OR obesity OR obese OR smoking OR tobacco OR alcohol OR exercise OR physical activity OR stress^*^ OR anesthesia OR radiation therapy OR oral contracepti^*^ OR fertility treatment OR pregnan^*^ OR breastfeed^*^ OR salt OR milk OR water OR trace elements OR trauma OR traumatic OR Epstein–Barr OR “Epstein barr”)

DATABASE SEARCHED & TIME PERIOD COVERED:

SCOPUS – ∼1800's-3/2/2015

LANGUAGE:

English

SEARCH STRATEGY #1:

TITLE-ABS-KEY(“multiple sclerosis”)

AND

TITLE-ABS-KEY(progression OR progressive OR progressing)

AND

TITLE-ABS-KEY(cohort OR prognos^*^OR predict^*^ OR multivariate)

SEARCH STRATEGY #2:

TITLE-ABS-KEY ( “multiple sclerosis”)

AND

TITLE-ABS-KEY ( progression OR progressive OR progressing )

AND

vitamin d OR fatty acid OR diet OR dietary OR nutrition^*^ OR obesity OR obese OR smoking OR tobacco OR alcohol ) OR ( geographic OR sun OR sunlight OR exercise OR physical activity OR stress^*^ OR anesthesia OR radiation therapy OR oral contracepti^*^ ) OR ( fertility treatment OR pregnan^*^ OR breastfeed^*^ OR salt OR milk OR water OR trace elements OR trauma OR traumatic OR epstein--barr OR “Epstein barr”

DATABASE SEARCHED & TIME PERIOD COVERED:

GreenFILE - ∼1970's- 3/2/2015

SEARCH STRATEGY:

“multiple sclerosis”

## SEARCH METHODOLOGY KQ2

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – Earliest-3/16/2015

LANGUAGE:

English

SEARCH STRATEGY:

multiple sclerosis

AND

United States Department of Veterans Affairs[mh] OR Veterans Health[mh] OR Hospitals, Veterans[mh] OR Veterans Disability Claims[mh] OR Veterans[mh] OR military personnel[mh] OR military medicine[mh] OR veteran^*^ or military or army or navy or naval or air force or marines or coast guard or national guard or soldier^*^ or guardsmen or reservist^*^ or troops or infantry^*^ or armed forces or armed service^*^ or war or wars or war-related or combat^*^ or battle^*^ or service-member^*^

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – Earliest-3/23/2015

LANGUAGE:

English

SEARCH STRATEGY:

‘multiple sclerosis’

AND

military OR army OR navy OR naval OR ‘air force’ OR marines OR ‘coast guard’ OR ‘national guard’ OR soldier^*^ OR guardsmen OR reservist^*^ OR troops OR infantry^*^ OR ‘armed forces’ OR ‘armed services’ OR war OR wars OR ‘war related’ OR combat^*^ OR battle^*^ OR ‘service member’ OR ‘service members’ OR ‘veteran’/exp OR ‘veteran’ OR veteran^*^:ti OR ‘veterans health’/de OR ‘veterans health’

DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science Indexes = SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH– 1/1/1980-3/23/2015

LANGUAGE:

English

SEARCH STRATEGY:

TOPIC: (“multiple sclerosis”)

AND

TOPIC: (veteran^*^ OR military OR army OR navy OR naval OR ‘air force’ OR marines OR ‘coast guard’ OR ‘national guard’ OR soldier^*^ OR guardsmen OR reservist^*^ OR troops OR infantry^*^ OR ‘armed forces’ OR ‘armed services’ OR war OR wars OR ‘war related’ OR combat^*^ OR battle^*^ OR ‘service member’ OR ‘service members’)

DATABASE SEARCHED & TIME PERIOD COVERED:

SCOPUS– Earliest-3/23/2015

LANGUAGE:

English

SEARCH STRATEGY:

TITLE-ABS-KEY(“multiple sclerosis”)

AND

ALL(veteran^*^ OR military OR army OR navy OR naval OR ‘air force’ OR marines OR ‘coast guard’ OR ‘national guard’ OR soldier^*^ OR guardsmen OR reservist^*^ OR troops OR infantry^*^ OR ‘armed forces’ OR ‘armed services’ OR war OR wars OR ‘war related’ OR combat^*^ OR battle OR ‘service member’ OR ‘service members’ )

DATABASE SEARCHED & TIME PERIOD COVERED:

AMED– Earliest-3/23/2015

LANGUAGE:

English

SEARCH STRATEGY:

ti(“multiple sclerosis”) OR su(“multiple sclerosis”)

AND

ab(veteran^*^ OR military OR army OR navy OR naval OR ‘air force’ OR marines OR ‘coast guard’ OR ‘national guard’ OR soldier^*^ OR guardsmen OR reservist^*^ OR troops OR infantry^*^ OR ‘armed forces’ OR ‘armed services’ OR war OR wars OR ‘war related’ OR combat^*^ OR battle^*^ OR ‘service member’ OR ‘service members’) OR ti(veteran^*^ OR military OR army OR navy OR naval OR ‘air force’ OR marines OR ‘coast guard’ OR ‘national guard’ OR soldier^*^ OR guardsmen OR reservist^*^ OR troops OR infantry^*^ OR ‘armed forces’ OR ‘armed services’ OR war OR wars OR ‘war related’ OR combat^*^ OR battle^*^ OR ‘service member’ OR ‘service members’) OR su(veteran^*^ OR military OR army OR navy OR naval OR ‘air force’ OR marines OR ‘coast guard’ OR ‘national guard’ OR soldier^*^ OR guardsmen OR reservist^*^ OR troops OR infantry^*^ OR ‘armed forces’ OR ‘armed services’ OR war OR wars OR ‘war related’ OR combat^*^ OR battle^*^ OR ‘service member’ OR ‘service members’)

DATABASE SEARCHED & TIME PERIOD COVERED:

GreenFILE– Earliest-3/23/2015

LANGUAGE:

English

SEARCH STRATEGY:

multiple sclerosis

NUMBER OF RESULTS: 49

DATABASE SEARCHED & TIME PERIOD COVERED:

Proquest Military Collection – Earliest-3/23/2015

LANGUAGE:

English

SEARCH STRATEGY:

(ti(“multiple sclerosis”) OR ab(“multiple sclerosis”) OR su(“multiple sclerosis”))

AND

(ab(veteran^*^ OR military OR army OR navy OR naval OR ‘air force’ OR marines OR ‘coast guard’ OR ‘national guard’ OR soldier^*^ OR guardsmen OR reservist^*^ OR troops OR infantry^*^ OR ‘armed forces’ OR ‘armed services’ OR war OR wars OR ‘war related’ OR combat^*^ OR battle^*^ OR ‘service member’ OR ‘service members’) OR ti(veteran^*^ OR military OR army OR navy OR naval OR ‘air force’ OR marines OR ‘coast guard’ OR ‘national guard’ OR soldier^*^ OR guardsmen OR reservist^*^ OR troops OR infantry^*^ OR ‘armed forces’ OR ‘armed services’ OR war OR wars OR ‘war related’ OR combat^*^ OR battle^*^ OR ‘service member’ OR ‘service members’) OR su(veteran^*^ OR military OR army OR navy OR naval OR ‘air force’ OR marines OR ‘coast guard’ OR ‘national guard’ OR soldier^*^ OR guardsmen OR reservist^*^ OR troops OR infantry^*^ OR ‘armed forces’ OR ‘armed services’ OR war OR wars OR ‘war related’ OR combat^*^ OR battle^*^ OR ‘service member’ OR ‘service members’))

DATABASE SEARCHED & TIME PERIOD COVERED:

DTIC Technical Reports Collections – Earliest-3/17/2015

SEARCH STRATEGY:

exact phrase: Multiple sclerosis

AND

Veterans

## SEARCH METHODOLOGY KQ3

This section documents the exact search strings used to identify studies relevant for KQ3.

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – Earliest-1/13/2015

FILTERS:

English, Randomized Controlled Trial

SEARCH STRATEGY:

“multiple sclerosis”

DATABASE SEARCHED & TIME PERIOD COVERED:

AMED – Earliest-3/3/2015

SEARCH STRATEGY:

“multiple sclerosis” AND interven^*^ AND (random^*^ OR rct^*^)

DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science – Earliest-3/3/2015

SEARCH STRATEGY:

TS = (multiple sclerosis)

AND

TS = (geographic OR sun OR sunlight OR vitamin D OR fatty acid OR diet OR dietary OR nutrition^*^ OR obesity OR obese OR smoking OR tobacco OR alcohol OR exercise OR physical activity OR stress^*^ OR anesthesia OR radiation therapy OR oral contracepti^*^ OR fertility treatment OR pregnan^*^ OR breastfeed^*^ OR salt OR milk OR water OR trace elements OR trauma OR traumatic OR Epstein–Barr OR “Epstein barr”))

AND

ts = (intervention^*^ OR intervene^*^)

AND

LANGUAGE: (English)